# REFERENCES

1 Goldzweig CL, Balekian TM, Rolon C, Yano EM, Shekelle PG. The state of women veterans' health research. Results of a systematic literature review. J Gen Intern Med. 2006;21 Suppl 3:S82-92.16637952
2 Bean-Mayberry B, Batuman F, Huang C, . Systematic review of women Veterans health research 2004-2008. VA-ESP Project #05-226; 2010.
3 Miake-Lye I, Hempel S, Shanman R, Shekelle PG. What is an evidence map? A systematic review of published eivdence maps and their definitions, methods, and products. Syst Rev. 2016;5:28.26864942
4 Barth S, Kimerling R, Pavao J, . Military sexual trauma among recent veterans: Correlates of sexual assault and sexual harassment. Am J Prev Med. 2016;50(1):77-86.26232906
5 Bell ME, Street AE, Stafford J. Victims' psychosocial well-being after reporting sexual harassment in the military. J Trauma Dissociation. 2014;15(2):133-152.24410254
6 Booth BM, Davis TD, Cheney AM, Mengeling MA, Torner JC, Sadler AG. Physical health status of female veterans: Contributions of sex partnership and in-military rape. Psychosom Med. 2012;74(9):916-924.23071345
7 Burnett-Zeigler I, Zivin K, Ilgen M, Szymanski B, Blow FC, Kales HC. Depression treatment in older adult veterans. Am J Geriatr Psychiatry. 2012;20(3):228-238.22354114
8 Davis TD, Deen TL, Fortney JC, Sullivan G, Hudson TJ. Utilization of VA mental health and primary care services among Iraq and Afghanistan veterans with depression: The influence of gender and ethnicity status. Mil Med. 2014;179(5):515-520.24806496
9 Dichter ME, Cerulli C, Bossarte RM. Intimate partner violence victimization among women veterans and associated heart health risks. Womens Health Issues. 2011;21(4 Suppl):S190-194.21724140
10 Dichter ME, Marcus SC, Wagner C, Bonomi AE. Associations between psychological, physical, and sexual intimate partner violence and health outcomes among women veteran VA patients. Soc Work Ment Health. 2014;12(5/6):411-428.
11 Dichter ME, Wagner C, Goldberg EB, Iverson KM. Intimate partner violence detection and care in the Veterans Health Administration: Patient and provider perspectives. Womens Health Issues. 2015;25(5):555-560.26227208
12 Dichter ME, Wagner C, True G. Timing of intimate partner violence in relationship to military service among women veterans. Mil Med. 2015;180(11):1124-1127.26540701
13 Forman-Hoffman VL, Mengeling M, Booth BM, Torner J, Sadler AG. Eating disorders, post-traumatic stress, and sexual trauma in women veterans. Mil Med. 2012;177(10):1161-1168.23113442
14 Gradus JL, Street AE, Kelly K, Stafford J. Sexual harassment experiences and harmful alcohol use in a military sample: Differences in gender and the mediating role of depression. J Stud Alcohol Drugs. 2008;69(3):348-351.18432376
15 Higgins DM, Dorflinger L, MacGregor KL, Heapy AA, Goulet JL, Ruser C. Binge eating behavior among a national sample of overweight and obese veterans. Obesity. 2013;21(5):900-903.23784891
16 Hyun JK, Kimerling R, Cronkite RC, McCutcheon S, Frayne SM. Organizational factors associated with screening for military sexual trauma. Womens Health Issues. 2012;22(2):e209-215.22055987
17 Iverson KM, Huang K, Wells SY, Wright JD, Gerber MR, Wiltsey-Stirman S. Women veterans' preferences for intimate partner violence screening and response procedures within the Veterans Health Administration. Res Nurs Health. 2014;37(4):302-311.24990824
18 Iverson KM, King MW, Gerber MR, . Accuracy of an intimate partner violence screening tool for female VHA patients: A replication and extension. J Trauma Stress. 2015;28(1):79-82.25624170
19 Iverson KM, King MW, Resick PA, Gerber MR, Kimerling R, Vogt D. Clinical utility of an intimate partner violence screening tool for female VHA patients. J Gen Intern Med. 2013;28(10):1288-1293.23824907
20 Iverson KM, Mercado R, Carpenter SL, Street AE. Intimate partner violence among women veterans: Previous interpersonal violence as a risk factor. J Trauma Stress. 2013;26(6):767-771.24243652
21 Iverson KM, Vogt D, Dichter ME, . Intimate partner violence and current mental health needs among female veterans. J Am Board Fam Med. 2015;28(6):772-776.26546653
22 Katz L, Cojucar G, Douglas S, Huffman C. Renew: An integrative psychotherapy program for women veterans with sexual trauma. J Contemp Psychother. 2014;44(3):163-171.
23 Katz LS, Cojucar G, Hoff RA, Lindl C, Huffman C, Drew T. Longitudinal outcomes of women veterans enrolled in the renew sexual trauma treatment program. J Contemp Psychother. 2015;45(3):143-150.
24 Klingensmith K, Tsai J, Mota N, Southwick SM, Pietrzak RH. Military sexual trauma in US veterans: Results from the National Health and Resilience in Veterans study. J Clin Psychiatry. 2014;75(10):e1133-1139.25373123
25 Lee EA, Bissett JK, Carter MA, . Preliminary findings of the relationship of lower heart rate variability with military sexual trauma and presumed posttraumatic stress disorder. J Trauma Stress. 2013;26(2):249-256.23568414
26 Li Z, Pfeiffer PN, Hoggatt KJ, . Emergent anxiety after antidepressant initiation: A retrospective cohort study of Veterans Affairs Health System patients with depression. Clin Ther. 2011;33(12):1985-1992.e1981.22177372
27 Litwack SD, Mitchell KS, Sloan DM, Reardon AF, Miller MW. Eating disorder symptoms and comorbid psychopathology among male and female veterans. Gen Hosp Psychiatry. 2014;36(4):406-410.24815590
28 Luterek JA, Bittinger JN, Simpson TL. Posttraumatic sequelae associated with military sexual trauma in female veterans enrolled in VA outpatient mental health clinics. J Trauma Dissociation. 2011;12(3):261-274.21534095
29 Mattocks KM, Haskell SG, Krebs EE, Justice AC, Yano EM, Brandt C. Women at war: Understanding how women veterans cope with combat and military sexual trauma. Soc Sci Med. 2012;74(4):537-545.22236641
30 McCall-Hosenfeld JS, Liebschutz JM, Spiro A, Seaver MR. Sexual assault in the military and its impact on sexual satisfaction in women veterans: A proposed model. J Womens Health. 2009;18(6):901-909.
31 Mitchell KS, Rasmusson A, Bartlett B, Gerber MR. Eating disorders and associated mental health comorbidities in female veterans. Psychiatry Res. 2014;219(3):589-591.25015710
32 Mitchell KS, Wolf EJ, Reardon AF, Miller MW. Association of eating disorder symptoms with internalizing and externalizing dimensions of psychopathology among men and women. Int J Eat Disord. 2014;47(8):860-869.24849585
33 Mohamed S, Leslie DL, Rosenheck RA. Use of antipsychotics in the treatment of major depressive disorder in the U.S. Department of Veterans Affairs. J Clin Psychiatry. Jun 2009;70(6):906-912.19422760
34 O'Brien C, Gaher RM, Pope C, Smiley P. Difficulty identifying feelings predicts the persistence of trauma symptoms in a sample of veterans who experienced military sexual trauma. J Nerv Ment Dis. 2008;196(3):252-255.18340263
35 Rowe EL, Gradus JL, Pineles SL, Batten SV, Davison EH. Military sexual trauma in treatment-seeking women veterans. Mil Psychol. 2009;21(3):387-395.
36 Smith BN, Shipherd JC, Schuster JL, Vogt DS, King LA, King DW. Posttraumatic stress symptomatology as a mediator of the association between military sexual trauma and post-deployment physical health in women. J Trauma Dissociation. 2011;12(3):275-289.21534096
37 Strauss JL, Marx CE, Weitlauf JC, . Is military sexual trauma associated with trading sex among women veterans seeking outpatient mental health care? J Trauma Dissociation. 2011;12(3):290-304.21534097
38 Street AE, Stafford J, Mahan CM, Hendricks A. Sexual harassment and assault experienced by reservists during military service: Prevalence and health correlates. J Rehabil Res Dev. 2008;45(3):409-419.18629749
39 Suris A, Link-Malcolm J, Chard K, Ahn C, North C. A randomized clinical trial of cognitive processing therapy for veterans with PTSD related to military sexual trauma. J Trauma Stress. 2013;26(1):28-37.23325750
40 Turchik JA, Pavao J, Hyun J, Mark H, Kimerling R. Utilization and intensity of outpatient care related to military sexual trauma for veterans from Afghanistan and Iraq. J Behav Health Serv Res. 2012;39(3):220-233.22396046
41 Turchik JA, Pavao J, Nazarian D, Iqbal S, McLean C, Kimerling R. Sexually transmitted infections and sexual dysfunctions among newly returned veterans with and without military sexual trauma. Int J Sex Health. 2012;24(1):45-59.
42 Valdez C, Kimerling R, Hyun JK, Mark HF, Saweikis M, Pavao J. Veterans Health Administration mental health treatment settings of patients who report military sexual trauma. J Trauma Dissociation. 2011;12(3):232-243.21534093
43 Voelkel E, Pukay-Martin ND, Walter KH, Chard KM. Effectiveness of cognitive processing therapy for male and female U.S. Veterans with and without military sexual trauma. J Trauma Stress. 2015;28(3):174-182.25976767
44 Walter KH, Buckley A, Simpson JM, Chard KM. Residential PTSD treatment for female veterans with military sexual trauma: Does a history of childhood sexual abuse influence outcome? J Interpers Violence. 2014;29(6):971-986.24162758
45 Castillo DT, J CdB, Qualls C, Bornovalova MA. Group exposure therapy treatment for post-traumatic stress disorder in female veterans. Mil Med. 2012;177(12):1486-1491.23397693
46 Castillo DT, Joseph JS, Tharp AT, . Externalizing and internalizing subtypes of posttraumatic psychopathology and anger expression. J Trauma Stress. 2014;27(1):108-111.24515536
47 Castillo DT, Lacefield K, C'De Baca J, Blankenship A, Qualls C. Effectiveness of group-delivered cognitive therapy and treatment length in women veterans with PTSD. Behav Sci. 2014;4(1):31-41.25379266
48 Decker SE, Rosenheck RA, Tsai J, Hoff R, Harpaz-Rotem I. Military sexual assault and homeless women veterans: Clinical correlates and treatment preferences. Womens Health Issues. 2013;23(6):e373-380.24183412
49 Erbes CR, Meis LA, Polusny MA, Compton JS. Couple adjustment and posttraumatic stress disorder symptoms in national guard veterans of the Iraq war. J Fam Psychol. 2011;25(4):479-487.21639633
50 Fontana A, Rosenheck R, Desai R. Female veterans of Iraq and Afghanistan seeking care from VA specialized PTSD programs: Comparison with male veterans and female war zone veterans of previous eras. J Womens Health. 2010;19(4):751-757.
51 Gallegos AM, Wolff KB, Streltzov NA, . Gender differences in service utilization among OEF/OIF veterans with posttraumatic stress disorder after a brief cognitive-behavioral intervention to increase treatment engagement: A mixed methods study. Womens Health Issues. 2015;25(5):542-547.26051022
52 Hall BJ, Elhai JD, Grubaugh A, Tuerk P, Magruder K. Examining the factor structure of PTSD between male and female veterans in primary care. J Anxiety Disord. 2012;26(3):409-415.22306134
53 Holliday R, Williams R, Bird J, Mullen K, Suris A. The role of cognitive processing therapy in improving psychosocial functioning, health, and quality of life in veterans with military sexual trauma-related posttraumatic stress disorder. Psychol Serv. 2015;12(4):428-434.26524285
54 Kelly MM, Vogt DS, Scheiderer EM, Ouimette P, Daley J, Wolfe J. Effects of military trauma exposure on women veterans' use and perceptions of Veterans Health Administration care. J Gen Intern Med. 2008;23(6):741-747.18414956
55 Kelly UA, Skelton K, Patel M, Bradley B. More than military sexual trauma: Interpersonal violence, PTSD, and mental health in women veterans. Res Nurs Health. 2011;34(6):457-467.21898452
56 Kimerling R, Pavao J, Valdez C, Mark H, Hyun JK, Saweikis M. Military sexual trauma and patient perceptions of Veteran Health Administration health care quality. Womens Health Issues. 2011;21(4 Suppl):S145-151.21724134
57 Kimerling R, Street AE, Gima K, Smith MW. Evaluation of universal screening for military-related sexual trauma. Psychiatr Serv. 2008;59(6):635-640.18511583
58 Kimerling R, Street AE, Pavao J, . Military-related sexual trauma among Veterans Health Administration patients returning from Afghanistan and Iraq. Am J Public Health. 2010;100(8):1409-1412.20558808
59 Kintzle S, Schuyler AC, Ray-Letourneau D, . Sexual trauma in the military: Exploring PTSD and mental health care utilization in female veterans. Psychol Serv. 2015;12(4):394-401.26524281
60 Lang AJ, Aarons GA, Gearity J, . Direct and indirect links between childhood maltreatment, posttraumatic stress disorder, and women's health. Behav Med. 2008;33(4):125-135.18316270
61 Lund BC, Bernardy NC, Vaughan-Sarrazin M, Alexander B, Friedman MJ. Patient and facility characteristics associated with benzodiazepine prescribing for veterans with PTSD. Psychiatr Serv. 2013;64(2):149-155.23154834
62 Lunney CA, Schnurr PP, Cook JM. Comparison of clinician- and self-assessments of posttraumatic stress symptoms in older versus younger veterans. J Trauma Stress. 2014;27(2):144-151.24700623
63 Marmar CR, Schlenger W, Henn-Haase C, . Course of posttraumatic stress disorder 40 years after the Vietnam War: Findings from the National Vietnam Veterans Longitudinal Study. JAMA Psychiatry. 2015;72(9):875-881.26201054
64 McDuffie E, Brown GR. 70 U.S. Veterans with gender identity disturbances: A descriptive study. Int J Transgend. 2010;12(1):21-30.
65 Mercado R, Ming Foynes M, Carpenter SL, Iverson KM. Sexual intimate partner violence as a form of MST: An initial investigation. Psychol Serv. 2015;12(4):348-356.26524276
66 Murdoch M, Pryor JB, Polusny MA, Wall MM, Ripley DC, Gackstetter GD. The association between military sexual stress and psychiatric symptoms after controlling for other stressors. J Psychiatr Res. 2010;44(16):1129-1136.21115147
67 Park CL, Wachen JS, Kaiser AP, Mager Stellman J. Cumulative trauma and midlife well-being in american women who served in Vietnam: Effects of combat exposure and postdeployment social support. Anxiety Stress Coping. 2015;28(2):144-161.25115369
68 Pavao J, Turchik JA, Hyun JK, . Military sexual trauma among homeless veterans. J Gen Intern Med. 2013;28 Suppl 2:S536-541.23807062
69 Pence PG, Katz LS, Huffman C, Cojucar G. Delivering integrative restoration-yoga nidra meditation (iRest) to women with sexual trauma at a Veteran's Medical Center: A pilot study. Int J Yoga Therap. 2014;24:53-62.
70 Rosen C, Adler E, Tiet Q. Presenting concerns of veterans entering treatment for posttraumatic stress disorder. J Trauma Stress. Oct 2013;26(5):640-643.24123262
71 Taft CT, Monson CM, Hebenstreit CL, King DW, King LA. Examining the correlates of aggression among male and female Vietnam veterans. Violence Vict. 2009;24(5):639-652.19852404
72 Tiet QQ, Leyva YE, Blau K, Turchik JA, Rosen CS. Military sexual assault, gender, and PTSD treatment outcomes of U.S. Veterans. J Trauma Stress. 2015;28(2):92-101.25847514
73 Vogt DS, Samper RE, King DW, King LA, Martin JA. Deployment stressors and posttraumatic stress symptomatology: Comparing active duty and National Guard/Reserve personnel from Gulf War I. J Trauma Stress. 2008;21(1):66-74.18302185
74 Westermeyer J, Canive J, Thuras P, Oakes M, Spring M. Pathological and problem gambling among veterans in clinical care: Prevalence, demography, and clinical correlates. Am J Addict. 2013;22(3):218-225.23617862
75 Berz JB, Taft CT, Watkins LE, Monson CM. Associations between PTSD symptoms and parenting satisfaction in a female veteran sample. J Psychol Trauma. 2008;7(1):37-45.
76 Blosnich JR, Dichter ME, Cerulli C, Batten SV, Bossarte RM. Disparities in adverse childhood experiences among individuals with a history of military service. JAMA Psychiatry. 2014;71(9):1041-1048.25054690
77 C'De Baca J, Castillo D, Qualls C. Ethnic differences in symptoms among female veterans diagnosed with PTSD. J Trauma Stress. 2012;25(3):353-357.22684719
78 Cobb Scott J, Pietrzak RH, Southwick SM, . Military sexual trauma interacts with combat exposure to increase risk for posttraumatic stress symptomatology in female Iraq and Afghanistan veterans. J Clin Psychiatry. 2014;75(6):637-643.25004187
79 Dutra L, Grubbs K, Greene C, . Women at war: Implications for mental health. J Trauma Dissociation. 2011;12(1):25-37.21240736
80 Fischer EP, Sherman MD, McSweeney JC, Pyne JM, Owen RR, Dixon LB. Perspectives of family and veterans on family programs to support reintegration of returning veterans with posttraumatic stress disorder. Psychol Serv. 2015;12(3):187-198.26213788
81 Freedy JR, Magruder KM, Mainous AG, Frueh BC, Geesey ME, Carnemolla M. Gender differences in traumatic event exposure and mental health among veteran primary care patients. Mil Med. 2010;175(10):750-758.20968265
82 Hawkins EJ, Malte CA, Grossbard JR, Saxon AJ. Prevalence and trends of concurrent opioid analgesic and benzodiazepine use among Veterans Affairs patients with post-traumatic stress disorder, 2003-2011. Pain Med. 2015;16(10):1943-1954.26332513
83 Hawkins EJ, Malte CA, Imel ZE, Saxon AJ, Kivlahan DR. Prevalence and trends of benzodiazepine use among Veterans Affairs patients with posttraumatic stress disorder, 2003-2010. Drug Alcohol Depend. 2012;124(1-2):154-161.22305658
84 Hebenstreit CL, Madden E, Koo KH, Maguen S. Minimally adequate mental health care and latent classes of PTSD symptoms in female Iraq and Afghanistan veterans. Psychiatry Res. 2015;230(1):90-95.26330305
85 Holowka DW, Marx BP, Gates MA, . Ptsd diagnostic validity in Veterans Affairs electronic records of Iraq and Afghanistan veterans. J Consult Clin Psychol. Aug 2014;82(4):569-579.24731235
86 Hughes J, Jouldjian S, Washington DL, Alessi CA, Martin JL. Insomnia and symptoms of post-traumatic stress disorder among women veterans. Behav Sleep Med. 2013;11(4):258-274.23205531
87 James LM, Belitskaya-Levy I, Lu Y, . Development and application of a diagnostic algorithm for posttraumatic stress disorder. Psychiatry Res. 2015;231(1):1-7.25433425
88 Katz L, Douglas S, Zaleski K, Williams J, Huffman C, Cojucar G. Comparing holographic reprocessing and prolonged exposure for women veterans with sexual trauma: A pilot randomized trial. J Contemp Psychother. 2014;44(1):9-19.
89 Katz LS, Snetter MR, Robinson AH, Hewitt P, Cojucar G. Holographic reprocessing: Empirical evidence to reduce posttraumatic cognitions in women veterans with PTSD from sexual trauma and abuse. Psychother. 2008;45(2):186-198.
90 Koo KH, Hebenstreit CL, Madden E, Maguen S. Ptsd detection and symptom presentation: Racial/ethnic differences by gender among veterans with PTSD returning from Iraq and Afghanistan. J Affect Disord. 2016;189:10-16.26402342
91 Lee EA, Theus SA. Lower heart rate variability associated with military sexual trauma rape and posttraumatic stress disorder. Biol Res Nurs. 2012;14(4):412-418.22899708
92 Lehavot K, Der-Martirosian C, Simpson TL, Shipherd JC, Washington DL. The role of military social support in understanding the relationship between PTSD, physical health, and healthcare utilization in women veterans. J Trauma Stress. 2013;26(6):772-775.24203114
93 Lehavot K, O'Hara R, Washington DL, Yano EM, Simpson TL. Posttraumatic stress disorder symptom severity and socioeconomic factors associated with Veterans Health Administration use among women veterans. Womens Health Issues. 2015;25(5):535-541.26123641
94 Metzger LJ, Carson MA, Lasko NB, . Basal and suppressed salivary cortisol in female Vietnam nurse veterans with and without PTSD. Psychiatry Res. 2008;161(3):330-335.18951637
95 Morland LA, Mackintosh MA, Rosen CS, . Telemedicine versus in-person delivery of cognitive processing therapy for women with posttraumatic stress disorder: A randomized noninferiority trial. Depress Anxiety. 2015;32(11):811-820.26243685
96 Renshaw KD, Campbell SB, Meis L, Erbes C. Gender differences in the associations of PTSD symptom clusters with relationship distress in U.S. Vietnam veterans and their partners. J Trauma Stress. 2014;27(3):283-290.24823939
97 Seal KH, Maguen S, Cohen B, . VA mental health services utilization in Iraq and Afghanistan veterans in the first year of receiving new mental health diagnoses. J Trauma Stress. Feb 2010;23(1):5-16.20146392
98 Shin HJ, Rosen CS, Greenbaum MA, Jain S. Longitudinal correlates of aggressive behavior in help-seeking U.S. Veterans with PTSD. J Trauma Stress. 2012;25(6):649-656.23225031
99 Tsai J, Rosenheck RA, Decker SE, Desai RA, Harpaz-Rotem I. Trauma experience among homeless female veterans: Correlates and impact on housing, clinical, and psychosocial outcomes. J Trauma Stress. 2012;25(6):624-632.23225030
100 Walter KH, Varkovitzky RL, Owens GP, Lewis J, Chard KM. Cognitive processing therapy for veterans with posttraumatic stress disorder: A comparison between outpatient and residential treatment. J Consult Clin Psychol. Aug 2014;82(4):551-561.24911422
101 Weitlauf JC, Finney JW, Ruzek JI, . Distress and pain during pelvic examinations: Effect of sexual violence. Obstet Gynecol. 2008;112(6):1343-1350.19037045
102 Weitlauf JC, Frayne SM, Finney JW, . Sexual violence, posttraumatic stress disorder, and the pelvic examination: How do beliefs about the safety, necessity, and utility of the examination influence patient experiences? J Womens Health. 2010;19(7):1271-1280.
103 Wolf EJ, Lunney CA, Miller MW, Resick PA, Friedman MJ, Schnurr PP. The dissociative subtype of PTSD: A replication and extension. Depress Anxiety. 2012;29(8):679-688.22639402
104 Wolf EJ, Miller MW, Orazem RJ, . The mmpi-2 restructured clinical scales in the assessment of posttraumatic stress disorder and comorbid disorders. Psychol Assess. 2008;20(4):327-340.19086756
105 Wolf EJ, Mitchell KS, Logue MW, . Corticotropin releasing hormone receptor 2 (crhr-2) gene is associated with decreased risk and severity of posttraumatic stress disorder in women. Depress Anxiety. 2013;30(12):1161-1169.24123648
106 Bernardy NC, Lund BC, Alexander B, Friedman MJ. Increased polysedative use in veterans with posttraumatic stress disorder. Pain Med. 2014;15(7):1083-1090.24341376
107 Bernardy NC, Lund BC, Alexander B, Jenkyn AB, Schnurr PP, Friedman MJ. Gender differences in prescribing among veterans diagnosed with posttraumatic stress disorder. J Gen Intern Med. 2013;28 Suppl 2:S542-548.23807063
108 Campbell R, Greeson MR, Bybee D, Raja S. The co-occurrence of childhood sexual abuse, adult sexual assault, intimate partner violence, and sexual harassment: A mediational model of posttraumatic stress disorder and physical health outcomes. J Consult Clin Psychol. 2008;76(2):194-207.18377117
109 Cohen BE, Maguen S, Bertenthal D, Shi Y, Jacoby V, Seal KH. Reproductive and other health outcomes in Iraq and Afghanistan women veterans using VA health care: Association with mental health diagnoses. Womens Health Issues. 2012;22(5):e461-471.22944901
110 Frayne SM, Chiu VY, Iqbal S, . Medical care needs of returning veterans with PTSD: Their other burden. J Gen Intern Med. 2011;26(1):33-39.20853066
111 Kimerling R, Serpi T, Weathers F, . Diagnostic accuracy of the composite international diagnostic interview (cidi 3.0) PTSD module among female Vietnam-era veterans. J Trauma Stress. 2014;27(2):160-167.24740869
112 King MW, Street AE, Gradus JL, Vogt DS, Resick PA. Gender differences in posttraumatic stress symptoms among OEF/OIF veterans: An item response theory analysis. J Trauma Stress. 2013;26(2):175-183.23526678
113 Koola MM, Qualls C, Kelly DL, . Prevalence of childhood physical and sexual abuse in veterans with psychiatric diagnoses. J Nerv Ment Dis. 2013;201(4):348-352.23538982
114 Magruder K, Serpi T, Kimerling R, . Prevalence of posttraumatic stress disorder in Vietnam-era women veterans: The health of Vietnam-era women's study (healthviews). JAMA Psychiatry. 2015;72(11):1127-1134.26445103
115 Maguen S, Cohen B, Cohen G, Madden E, Bertenthal D, Seal K. Gender differences in health service utilization among Iraq and Afghanistan veterans with posttraumatic stress disorder. J Womens Health. 2012;21(6):666-673.
116 Maguen S, Cohen B, Ren L, Bosch J, Kimerling R, Seal K. Gender differences in military sexual trauma and mental health diagnoses among Iraq and Afghanistan veterans with posttraumatic stress disorder. Womens Health Issues. 2012;22(1):e61-66.21907590
117 Maguen S, Madden E, Neylan TC, Cohen BE, Bertenthal D, Seal KH. Timing of mental health treatment and PTSD symptom improvement among Iraq and Afghanistan veterans. Psychiatr Serv. 2014;65(12):1414-1419.25082217
118 Mattocks KM, Skanderson M, Goulet JL, . Pregnancy and mental health among women veterans returning from Iraq and Afghanistan. J Womens Health. 2010;19(12):2159-2166.
119 McCauley HL, Blosnich JR, Dichter ME. Adverse childhood experiences and adult health outcomes among veteran and non-veteran women. J Womens Health. 2015;24(9):723-729.
120 Mercado RC, Wiltsey-Stirman S, Iverson KM. Impact of childhood abuse on physical and mental health status and health care utilization among female veterans. Mil Med. 2015;180(10):1065-1074.26444469
121 Myers CE, Vanmeenen KM, Servatius RJ. Behavioral inhibition and PTSD symptoms in veterans. Psychiatry Res. 2012;196(2-3):271-276.22397911
122 Nillni YI, Gradus JL, Gutner CA, Luciano MT, Shipherd JC, Street AE. Deployment stressors and physical health among OEF/OIF veterans: The role of PTSD. Health Psychol. 2014;33(11):1281-1287.25020154
123 Polusny MA, Dickinson KA, Murdoch M, Thuras P. The role of cumulative sexual trauma and difficulties identifying feelings in understanding female veterans' physical health outcomes. Gen Hosp Psychiatry. 2008;30(2):162-170.18291298
124 Sayer NA, Hagel EM, Noorbaloochi S, . Gender differences in VA disability status for PTSD over time. Psychiatr Serv. 2014;65(5):663-669.24535436
125 Schnurr PP, Lunney CA. Exploration of gender differences in how quality of life relates to posttraumatic stress disorder in male and female veterans. J Rehabil Res Dev. 2008;45(3):383-393.18629747
126 Schnurr PP, Lunney CA. Work-related quality of life and posttraumatic stress disorder symptoms among female veterans. Womens Health Issues. 2011;21(4 Suppl):S169-175.21724137
127 Schnurr PP, Lunney CA. Work-related outcomes among female veterans and service members after treatment of posttraumatic stress disorder. Psychiatr Serv. 2012;63(11):1072-1079.22983600
128 Schnurr PP, Lunney CA. Differential effects of prolonged exposure on posttraumatic stress disorder symptoms in female veterans. J Consult Clin Psychol. 2015;83(6):1154-1160.26147562
129 Schnurr PP, Lunney CA, Forshay E, . Sexual function outcomes in women treated for posttraumatic stress disorder. J Womens Health. 2009;18(10):1549-1557.
130 Shaw JG, Asch SM, Kimerling R, Frayne SM, Shaw KA, Phibbs CS. Posttraumatic stress disorder and risk of spontaneous preterm birth. Obstet Gynecol. 2014;124(6):1111-1119.25415162
131 Stricker NH, Keller JE, Castillo DT, Haaland KY. The neurocognitive performance of female veterans with posttraumatic stress disorder. J Trauma Stress. 2015;28(2):102-109.25847622
132 Teh CF, Kilbourne AM, McCarthy JF, Welsh D, Blow FC. Gender differences in health-related quality of life for veterans with serious mental illness. Psychiatr Serv. 2008;59(6):663-669.18511587
133 Washington DL, Davis TD, Der-Martirosian C, Yano EM. Ptsd risk and mental health care engagement in a multi-war era community sample of women veterans. J Gen Intern Med. 2013;28(7):894-900.23435765
134 Blow FC, Bohnert AS, Ilgen MA, . Suicide mortality among patients treated by the Veterans Health Administration from 2000 to 2007. Am J Public Health. Mar 2012;102 Suppl 1:S98-104.22390612
135 Charlotte M, Schwartz E, Slade E, . Gender differences in mood stabilizer medications prescribed to veterans with serious mental illness. J Affect Disord. 2015;188:112-117.26361066
136 Chavez LJ, Williams EC, Lapham G, Bradley KA. Association between alcohol screening scores and alcohol-related risks among female Veterans Affairs patients. J Stud Alcohol Drugs. 2012;73(3):391-400.22456244
137 Creech SK, Borsari B. Alcohol use, military sexual trauma, expectancies, and coping skills in women veterans presenting to primary care. Addict Behav. 2014;39(2):379-385.23498717
138 Denneson LM, Lasarev MR, Dickinson KC, Dobscha SK. Alcohol consumption and health status in very old veterans. J Geriatr Psychiatry Neurol. 2011;24(1):39-43.21156988
139 Fang SC, Schnurr PP, Kulish AL, . Psychosocial functioning and health-related quality of life associated with posttraumatic stress disorder in male and female Iraq and Afghanistan War veterans: The VALOR registry. J Womens Health. 2015;24(12):1038-1046.
140 Hawkins EJ, Lapham GT, Kivlahan DR, Bradley KA. Recognition and management of alcohol misuse in OEF/OIF and other veterans in the VA: A cross-sectional study. Drug Alcohol Depend. 2010;109(1-3):147-153.20167440
141 Heslin KC, Gable A, Dobalian A. Special services for women in substance use disorders treatment: How does the Department of Veterans Affairs compare with other providers? Womens Health Issues. 2015;25(6):666-672.26329259
142 Hoffmire CA, Bossarte RM. A reconsideration of the correlation between veteran status and firearm suicide in the general population. Inj Prev. 2014;20(5):317-321.24670958
143 Hoggatt KJ, Williams EC, Der-Martirosian C, Yano EM, Washington DL. National prevalence and correlates of alcohol misuse in women veterans. J Subst Abuse Treat. 2015;52:10-16.25661517
144 Ilgen MA, Bohnert AS, Ignacio RV, . Psychiatric diagnoses and risk of suicide in veterans. Arch Gen Psychiatry. 2010;67(11):1152-1158.21041616
145 Kaplan MS, McFarland BH, Huguet N. Firearm suicide among veterans in the general population: Findings from the national violent death reporting system. J Trauma. 2009;67(3):503-507.19741391
146 Kaplan MS, McFarland BH, Huguet N, . Acute alcohol intoxication and suicide: A gender-stratified analysis of the national violent death reporting system. Inj Prev. 2013;19(1):38-43.22627777
147 Kelley ML, Brancu M, Robbins AT, . Drug use and childhood-, military- and post-military trauma exposure among women and men veterans. Drug Alcohol Depend. 2015;152:201-208.25957156
148 Kelley ML, Runnals J, Pearson MR, . Alcohol use and trauma exposure among male and female veterans before, during, and after military service. Drug Alcohol Depend. 2013;133(2):615-624.24054989
149 Lapham GT, Rubinsky AD, Heagerty PJ, . Probability and predictors of patients converting from negative to positive screens for alcohol misuse. Alcohol Clin Exp Res. 2014;38(2):564-571.24118025
150 Lapham GT, Rubinsky AD, Heagerty PJ, . Annual rescreening for alcohol misuse: Diminishing returns for some patient subgroups. Med Care. Oct 2013;51(10):914-921.23969582
151 Lapham GT, Rubinsky AD, Williams EC, . Decreasing sensitivity of clinical alcohol screening with the audit-c after repeated negative screens in VA clinics. Drug Alcohol Depend. 2014;142:209-215.25034900
152 Lehavot K, Browne KC, Simpson TL. Examining sexual orientation disparities in alcohol misuse among women veterans. Am J Prev Med. 2014;47(5):554-562.25241197
153 Lemaire CM, Graham DP. Factors associated with suicidal ideation in OEF/OIF veterans. J Affect Disord. 2011;130(1-2):231-238.21055828
154 McCarthy JF, Blow FC, Ignacio RV, Ilgen MA, Austin KL, Valenstein M. Suicide among patients in the Veterans Affairs Health System: Rural-urban differences in rates, risks, and methods. Am J Public Health. Mar 2012;102 Suppl 1:S111-117.22390583
155 McCarthy JF, Szymanski BR, Karlin BE, Katz IR. Suicide mortality following nursing home discharge in the Department of Veterans Affairs Health System. Am J Public Health. Dec 2013;103(12):2261-2266.24134359
156 McCarthy JF, Valenstein M, Kim HM, Ilgen M, Zivin K, Blow FC. Suicide mortality among patients receiving care in the Veterans Health Administration health system. Am J Epidemiol. 2009;169(8):1033-1038.19251753
157 Miles SR, Graham DP, Teng EJ. Examining the influence of mild traumatic brain injury and posttraumatic stress disorder on alcohol use disorder in OEF/OIF veterans. Mil Med. 2015;180(1):45-52.25562857
158 Oliva EM, Gregor A, Rogers J, Dalton A, Harris AHS, Trafton JA. Correlates of specialty substance use disorder treatment among female patients in the Veterans Health Administration. J Soc Work Pract Addict. 2012;12(3):282-301.
159 Oliva EM, Harris AH, Trafton JA, Gordon AJ. Receipt of opioid agonist treatment in the Veterans Health Administration: Facility and patient factors. Drug Alcohol Depend. May 1 2012;122(3):241-246.22115887
160 Schlenger WE, Corry NH, Williams CS, . A prospective study of mortality and trauma-related risk factors among a nationally representative sample of Vietnam veterans. Am J Epidemiol. 2015;182(12):980-990.26634285
161 Schwartz E, Charlotte M, Slade E, . Gender differences in antipsychotics prescribed to veterans with serious mental illness. Gen Hosp Psychiatry. 2015;37(4):347-351.25936673
162 Scott JC, Pietrzak RH, Mattocks K, Southwick SM, Brandt C, Haskell S. Gender differences in the correlates of hazardous drinking among Iraq and Afghanistan veterans. Drug Alcohol Depend. 2013;127(1-3):15-22.22770463
163 Seal KH, Cohen G, Waldrop A, Cohen BE, Maguen S, Ren L. Substance use disorders in Iraq and Afghanistan veterans in VA healthcare, 2001-2010; implications for screening, diagnosis, and treatment. Drug Alcohol Depend. 2011;116:93-101.21277712
164 Wallace AE, Sheehan EP, Young-Xu Y. Women, alcohol, and the military: Cultural changes and reductions in later alcohol problems among female veterans. J Womens Health. 2009;18(9):1347-1353.
165 Westermeyer J, Canive J, Thuras P, Thompson J, Crosby RD, Garrard J. A comparison of substance use disorder severity and course in american indian male and female veterans. Am J Addict. 2009;18(1):87-92.19219670
166 Williams EC, Rubinsky AD, Lapham GT, . Prevalence of clinically recognized alcohol and other substance use disorders among VA outpatients with unhealthy alcohol use identified by routine alcohol screening. Drug Alcohol Depend. Feb 1 2014;135:95-103.24360928
167 Abdullah KN, Janardhan R, Hwang M, . Adjuvant radiation therapy for breast cancer in patients with schizophrenia. Am J Surg. 2015;209(2):378-384.25450588
168 Booth BM, Mengeling M, Torner J, Sadler AG. Rape, sex partnership, and substance use consequences in women veterans. J Trauma Stress. 2011;24(3):287-294.21567476
169 Bradley CS, Nygaard IE, Mengeling MA, . Urinary incontinence, depression and posttraumatic stress disorder in women veterans. Am J Obstet Gynecol. 2012;206(6):502.e501-508.22631867
170 Bradley CS, Nygaard IE, Torner JC, Hillis SL, Johnson S, Sadler AG. Overactive bladder and mental health symptoms in recently deployed female veterans. J Urol. 2014;191(5):1327-1332.24316095
171 Bradley KA, Rubinsky AD, Sun H, . Prevalence of alcohol misuse among men and women undergoing major noncardiac surgery in the Veterans Affairs Health Care System. Surgery. 2012;152(1):69-81.22503319
172 Breland JY, Greenbaum MA, Zulman DM, Rosen CS. The effect of medical comorbidities on male and female veterans' use of psychotherapy for PTSD. Med Care. 2015;53(4 Suppl 1):S120-127.25767965
173 Callegari LS, Zhao X, Nelson KM, Borrero S. Contraceptive adherence among women veterans with mental illness and substance use disorder. Contraception. 2015;91(5):386-392.25636807
174 Callegari LS, Zhao X, Nelson KM, Lehavot K, Bradley KA, Borrero S. Associations of mental illness and substance use disorders with prescription contraception use among women veterans. Contraception. 2014;90(1):97-103.24731860
175 Cheney AM, Booth BM, Davis TD, Mengeling MA, Torner JC, Sadler AG. The role of borderline personality disorder and depression in the relationship between sexual assault and body mass index among women veterans. Violence Vict. 2014;29(5):742-756.25905125
176 Duffy AR, Beckie TM, Brenner LA, . Relationship between toxoplasma gondii and mood disturbance in women veterans. Mil Med. 2015;180(6):621-625.26032378
177 Gutierrez PM, Brenner LA, Rings JA, . A qualitative description of female veterans' deployment-related experiences and potential suicide risk factors. J Clin Psychol. 2013;69(9):923-935.23775338
178 Haskell SG, Papas RK, Heapy A, Reid MC, Kerns RD. The association of sexual trauma with persistent pain in a sample of women veterans receiving primary care. Pain Med. 2008;9(6):710-717.18565005
179 Huguet N, Kaplan MS, McFarland BH. The effects of misclassification biases on veteran suicide rate estimates. Am J Public Health. 2014;104(1):151-155.24228669
180 Klausner AP, Ibanez D, King AB, . The influence of psychiatric comorbidities and sexual trauma on lower urinary tract symptoms in female veterans. J Urol. 2009;182(6):2785-2790.19850303
181 Maguen S, Madden E, Cohen B, Bertenthal D, Seal K. Association of mental health problems with gastrointestinal disorders in Iraq and Afghanistan veterans. Depress Anxiety. 2014;31(2):160-165.23494973
182 Runnals JJ, Van Voorhees E, Robbins AT, . Self-reported pain complaints among Afghanistan/Iraq era men and women veterans with comorbid posttraumatic stress disorder and major depressive disorder. Pain Med. 2013;14(10):1529-1533.23924351
183 Sambamoorthi U, Shen C, Findley P, Frayne S, Banerjea R. Depression treatment patterns among women veterans with cardiovascular conditions or diabetes. World Psychiatry. 2010;9(3):177-182.20975865
184 Savas LS, White DL, Wieman M, . Irritable bowel syndrome and dyspepsia among women veterans: Prevalence and association with psychological distress. Aliment Pharmacol Ther. 2009;29(1):115-125.18785989
185 Seng EK, Driscoll MA, Brandt CA, . Prescription headache medication in OEF/OIF veterans: Results from the women veterans cohort study. Headache. 2013;53(8):1312-1322.23808756
186 Shen C, Findley P, Banerjea R, Sambamoorthi U. Depressive disorders among cohorts of women veterans with diabetes, heart disease, and hypertension. J Womens Health. 2010;19(8):1475-1486.
187 Viverito K, Owen R, Mittal D, Li C, Williams JS. Management of new hyperglycemia in patients prescribed antipsychotics. Psychiatr Serv. 2014;65(12):1502-1505.25179283
188 Wachen JS, Shipherd JC, Suvak M, Vogt D, King LA, King DW. Posttraumatic stress symptomatology as a mediator of the relationship between warzone exposure and physical health symptoms in men and women. J Trauma Stress. 2013;26(3):319-328.23695839
189 Weiner J, Richmond TS, Conigliaro J, Wiebe DJ. Military veteran mortality following a survived suicide attempt. BMC Public Health. 2011;11:374.21605448
190 Weitlauf JC, Jones S, Xu X, . Receipt of cervical cancer screening in female veterans: Impact of posttraumatic stress disorder and depression. Womens Health Issues. 2013;23(3):e153-159.23660429
191 White DL, Savas LS, Daci K, . Trauma history and risk of the irritable bowel syndrome in women veterans. Aliment Pharmacol Ther. 2010;32(4):551-561.20528828
192 White JR, Chang CC, So-Armah KA, . Depression and human immunodeficiency virus infection are risk factors for incident heart failure among veterans: Veterans aging cohort study. Circulation. 2015;132(17):1630-1638.26358261
193 Wisco BE, Marx BP, Holowka DW, . Traumatic brain injury, PTSD, and current suicidal ideation among Iraq and Afghanistan U.S. Veterans. J Trauma Stress. 2014;27(2):244-248.24639101
194 Banerjea R, Pogach LM, Smelson D, Sambamoorthi U. Mental illness and substance use disorders among women veterans with diabetes. Womens Health Issues. 2009;19(6):446-456.19879456
195 C'De Baca J, Castillo DT, Mackaronis JE, Qualls C. Ethnic differences in personality disorder patterns among women veterans diagnosed with PTSD. Behav Sci. 2014;4(1):72-86.25379270
196 Chatterjee S, Rath ME, Spiro A, 3rd, Eisen S, Sloan KL, Rosen AK. Gender differences in Veterans Health Administration mental health service use: Effects of age and psychiatric diagnosis. Womens Health Issues. 2009;19(3):176-184.19447322
197 Cochran BN, Balsam K, Flentje A, Malte CA, Simpson T. Mental health characteristics of sexual minority veterans. J Homosex. 2013;60(2-3):419-435.23414280
198 Correa R, Parry B. Women's mental health clinic: A naturalistic description of the population attended in the san diego VA health care system during a one year period. J Affect Disord. 2012;142(1-3):31-35.22889523
199 Desai RA, Harpaz-Rotem I, Najavits LM, Rosenheck RA. Impact of the Seeking Safety program on clinical outcomes among homeless female veterans with psychiatric disorders. Psychiatr Serv. 2008;59(9):996-1003.18757592
200 Finlay AK, Binswanger IA, Smelson D, . Sex differences in mental health and substance use disorders and treatment entry among justice-involved veterans in the Veterans Health Administration. Med Care. 2015;53(4 Suppl 1):S105-111.25767963
201 Koo KH, Hebenstreit CL, Madden E, Seal KH, Maguen S. Race/ethnicity and gender differences in mental health diagnoses among Iraq and Afghanistan veterans. Psychiatry Res. 2015;229(3):724-731.26282226
202 Lehavot K, Simpson TL. Trauma, posttraumatic stress disorder, and depression among sexual minority and heterosexual women veterans. J Couns Psychol. 2014;61(3):392-403.25019543
203 Maguen S, Cohen B, Cohen G, Madden E, Bertenthal D, Seal K. Eating disorders and psychiatric comorbidity among Iraq and Afghanistan veterans. Womens Health Issues. 2012;22(4):e403-406.22749199
204 Maguen S, Ren L, Bosch JO, Marmar CR, Seal KH. Gender differences in mental health diagnoses among Iraq and Afghanistan veterans enrolled in Veterans Affairs health care. Am J Public Health. 2010;100(12):2450-2456.20966380
205 Mattocks KM, Sadler A, Yano EM, . Sexual victimization, health status, and VA healthcare utilization among lesbian and bisexual OEF/OIF veterans. J Gen Intern Med. 2013;28 Suppl 2:S604-608.23807072
206 Miller LJ, Ghadiali NY. Gender-specific mental health care needs of women veterans treated for psychiatric disorders in a veterans administration women's health clinic. Med Care. 2015;53(4 Suppl 1):S93-96.25767984
207 Nunnink SE, Goldwaser G, Heppner PS, Pittman JO, Nievergelt CM, Baker DG. Female veterans of the OEF/OIF conflict: Concordance of PTSD symptoms and substance misuse. Addict Behav. 2010;35(7):655-659.20378259
208 Reddy S, Dick AM, Gerber MR, Mitchell K. The effect of a yoga intervention on alcohol and drug abuse risk in veteran and civilian women with posttraumatic stress disorder. J Altern Complement Med. 2014;20(10):750-756.25211372
209 Ryan ET, McGrath AC, Creech SK, Borsari B. Predicting utilization of healthcare services in the Veterans Health Administration by returning women veterans: The role of trauma exposure and symptoms of posttraumatic stress. Psychol Serv. 2015;12(4):412-419.26524283
210 Zinzow HM, Grubaugh AL, Frueh BC, Magruder KM. Sexual assault, mental health, and service use among male and female veterans seen in Veterans Affairs primary care clinics: A multi-site study. Psychiatry Res. 2008;159(1-2):226-236.18423615
211 Lopez MR, Cheng JY, Kanner AM, Carvalho DZ, Diamond JA, Wallace DM. Insomnia symptoms in south florida military veterans with epilepsy. Epilepsy Behav. 2013;27(1):159-164.23434722
212 Mohanty AF, Muthukutty A, Carter ME, . Chronic multisymptom illness among female veterans deployed to Iraq and Afghanistan. Med Care. 2015;53(4 Suppl 1):S143-148.25767968
213 Nazarian D, Kimerling R, Frayne SM. Posttraumatic stress disorder, substance use disorders, and medical comorbidity among returning U.S. Veterans. J Trauma Stress. 2012;25(2):220-225.22522739
214 Steinman MA, Lee SJ, John Boscardin W, . Patterns of multimorbidity in elderly veterans. J Am Geriatr Soc. 2012;60(10):1872-1880.23035702
215 Tyson GL, Kramer JR, Duan Z, Davila JA, Richardson PA, El-Serag HB. Prevalence and predictors of hepatitis b virus coinfection in a United States cohort of hepatitis c virus-infected patients. Hepatology. 2013;58(2):538-545.23505059
216 Volkman JE, DeRycke EC, Driscoll MA, . Smoking status and pain intensity among OEF/OIF/OND veterans. Pain Med. 2015;16(9):1690-1696.25917639
217 Womack JA, Chang CC, So-Armah KA, . HIV infection and cardiovascular disease in women. J Am Heart Assoc. 2014;3(5):e001035.25324353
218 Brown GR, Jones KT. Incidence of breast cancer in a cohort of 5,135 transgender veterans. Breast Cancer Res Treat. 2015;149(1):191-198.25428790
219 Bush RL, Kallen MA, Liles DR, Bates JT, Petersen LA. Knowledge and awareness of peripheral vascular disease are poor among women at risk for cardiovascular disease. J Surg Res. 2008;145(2):313-319.18222479
220 Canter DL, Atkins MD, McNeal CJ, Bush RL. Risk factor treatment in veteran women at risk for cardiovascular disease. J Surg Res. 2009;157(2):175-180.19482299
221 Colonna S, Halwani A, Ying J, Buys S, Sweeney C. Women with breast cancer in the Veterans Health Administration: Demographics, breast cancer characteristics, and trends. Med Care. 2015;53(4 Suppl 1):S149-155.25767969
222 Davis MB, Maddox TM, Langner P, Plomondon ME, Rumsfeld JS, Duvernoy CS. Characteristics and outcomes of women veterans undergoing cardiac catheterization in the Veterans Affairs Healthcare System: Insights from the VA cart program. Circ Cardiovasc Qual Outcomes. 2015;8(2 Suppl 1):S39-47.25714820
223 Goldstein KM, Melnyk SD, Zullig LL, . Heart matters: Gender and racial differences cardiovascular disease risk factor control among veterans. Womens Health Issues. 2014;24(5):477-483.25213741
224 Johnson RG, Wittgen CM, Hutter MM, Henderson WG, Mosca C, Khuri SF. Comparison of risk-adjusted 30-day postoperative mortality and morbidity in Department of Veterans Affairs hospitals and selected university medical centers: Vascular surgical operations in women. J Am Coll Surg. Jun 2007;204(6):1137-1146.17544072
225 Kvasnovsky CL, Kesmodel SB, Gragasin JL, . Expansion of screening mammography in the Veterans Health Administration: Implications for breast cancer treatment. JAMA Surgery. 2013;148(11):999-1004.24048217
226 Leong M, Chike-Obi CJ, Basu CB, Lee EI, Albo D, Netscher DT. Effective breast reconstruction in female veterans. Am J Surg. 2009;198(5):658-663.19887195
227 Luther SL, Neumayer L, Henderson WG, . The use of breast-conserving surgery for women treated for breast cancer in the Department of Veterans Affairs. Am J Surg. 2013;206(1):72-79.23611837
228 McQueen A, Swank PR, Bastian LA, Vernon SW. Predictors of perceived susceptibility of breast cancer and changes over time: A mixed modeling approach. Health Psychol. 2008;27(1):68-77.18230016
229 Rose DE, Farmer MM, Yano EM, Washington DL. Racial/ethnic differences in cardiovascular risk factors among women veterans. J Gen Intern Med. 2013;28 Suppl 2:S524-528.23807060
230 Sambamoorthi U, Mitra S, Findley PA, Pogach LM. Decomposing gender differences in low-density lipoprotein cholesterol among veterans with or at risk for cardiovascular illness. Womens Health Issues. 2012;22(2):e201-208.22133598
231 Vimalananda VG, Miller DR, Christiansen CL, Wang W, Tremblay P, Fincke BG. Cardiovascular disease risk factors among women veterans at VA medical facilities. J Gen Intern Med. 2013;28 Suppl 2:S517-523.23807059
232 Vimalananda VG, Miller DR, Palnati M, Christiansen CL, Fincke BG. Gender disparities in lipid-lowering therapy among veterans with diabetes. Womens Health Issues. 2011;21(4 Suppl):S176-181.21724138
233 Virani SS, Woodard LD, Chitwood SS, . Frequency and correlates of treatment intensification for elevated cholesterol levels in patients with cardiovascular disease. Am Heart J. 2011;162(4):725-732.e721.21982666
234 Virani SS, Woodard LD, Ramsey DJ, . Gender disparities in evidence-based statin therapy in patients with cardiovascular disease. Am J Cardiol. 2015;115(1):21-26.25456865
235 Wheeler S, Bowen JD, Maynard C, . Women veterans and outcomes after acute myocardial infarction. J Womens Health. 2009;18(5):613-618.
236 Wheeler S, Moore K, Forsberg CW, . Mortality among veterans with type 2 diabetes initiating metformin, sulfonylurea or rosiglitazone monotherapy. Diabetologia. 2013;56(9):1934-1943.23797633
237 Arterburn D, Livingston EH, Olsen MK, . Predictors of initial weight loss after gastric bypass surgery in twelve Veterans Affairs Medical Centers. Obes Res Clin Pract. 2013;7(5):e367-376.24304479
238 Arterburn DE, Olsen MK, Smith VA, . Association between bariatric surgery and long-term survival. JAMA. 2015;313(1):62-70.25562267
239 Backus L, Czarnogorski M, Yip G, . HIV care continuum applied to the US Department of Veterans Affairs: HIV virologic outcomes in an integrated health care system. J Acquir Immune Defic Syndr. 2015;69(4):474-480.25835603
240 Bedimo RJ, McGinnis KA, Dunlap M, Rodriguez-Barradas MC, Justice AC. Incidence of non-aids-defining malignancies in HIV-infected versus noninfected patients in the haart era: Impact of immunosuppression. J Acquir Immune Defic Syndr. 2009;52(2):203-208.19617846
241 Blackstock OJ, Tate JP, Akgun KM, . Sex disparities in overall burden of disease among HIV-infected individuals in the Veterans Affairs Healthcare System. J Gen Intern Med. 2013;28 Suppl 2:S577-582.23807068
242 Brown DW. Smoking prevalence among US veterans. J Gen Intern Med. 2010;25(2):147-149.19894079
243 Cameron MH, Poel AJ, Haselkorn JK, Linke A, Bourdette D. Falls requiring medical attention among veterans with multiple sclerosis: A cohort study. J Rehabil Res Dev. 2011;48(1):13-20.21328159
244 Curtin CM, Suarez PA, Di Ponio LA, Frayne SM. Who are the women and men in Veterans Health Administration's current spinal cord injury population? J Rehabil Res Dev. 2012;49(3):351-360.22773195
245 Czarnogorski M, Halloran Cns J, Pedati C, . Expanded HIV testing in the US Department of Veterans Affairs, 2009-2011. Am J Public Health. 2013;103(12):e40-45.24134344
246 Del Re AC, Frayne SM, Harris AH. Antiobesity medication use across the Veterans Health Administration: Patient-level predictors of receipt. Obesity. 2014;22(9):1968-1972.24931332
247 Iverson KM, Hendricks AM, Kimerling R, . Psychiatric diagnoses and neurobehavioral symptom severity among OEF/OIF VA patients with deployment-related traumatic brain injury: A gender comparison. Womens Health Issues. 2011;21(4 Suppl):S210-217.21724143
248 Iverson KM, Pogoda TK. Traumatic brain injury among women veterans: An invisible wound of intimate partner violence. Med Care. 2015;53(4 Suppl 1):S112-119.25767964
249 Iverson KM, Pogoda TK, Gradus JL, Street AE. Deployment-related traumatic brain injury among Operation Enduring Freedom/Operation Iraqi Freedom veterans: Associations with mental and physical health by gender. J Womens Health. 2013;22(3):267-275.
250 Katzburg JR, Farmer MM, Poza IV, Sherman SE. Listen to the consumer: Designing a tailored smoking-cessation program for women. Subst Use Misuse. 2008;43(8-9):1240-1259.18649241
251 Katzburg JR, Yano EM, Washington DL, . Combining women's preferences and expert advice to design a tailored smoking cessation program. Subst Use Misuse. 2009;44(14):2114-2137.20001698
252 Khurana SR, Bamer AM, Turner AP, . The prevalence of overweight and obesity in veterans with multiple sclerosis. Am J Phys Med Rehabil. 2009;88(2):83-91.19169174
253 Littman AJ, Boyko EJ, McDonell MB, Fihn SD. Evaluation of a weight management program for veterans. Prev Chronic Dis. 2012;9:E99.22595323
254 Littman AJ, Jacobson IG, Boyko EJ, Powell TM, Smith TC, Millennium Cohort Study Team. Weight change following US military service. Int J Obes. 2013;37(2):244-253.
255 Maguen S, Madden E, Cohen B, . The relationship between body mass index and mental health among Iraq and Afghanistan veterans. J Gen Intern Med. 2013;28 Suppl 2:S563-570.23807066
256 Nayak SU, Welch ML, Kan VL. Greater HIV testing after Veterans Health Administration policy change: The experience from a VA Medical Center in a high HIV prevalence area. J Acquir Immune Defic Syndr. 2012;60(2):165-168.22627183
257 Pogoda TK, Hendricks AM, Iverson KM, . Multisensory impairment reported by veterans with and without mild traumatic brain injury history. J Rehabil Res Dev. 2012;49(7):971-984.23341273
258 Rogers TJ, Smith BM, Weaver FM, . Healthcare utilization following mild traumatic brain injury in female veterans. Brain Inj. 2014;28(11):1406-1412.24945602
259 Rosenberger PH, Ning Y, Brandt C, Allore H, Haskell S. Bmi trajectory groups in veterans of the Iraq and Afghanistan Wars. Prev Med. 2011;53(3):149-154.21771610
260 Vimalananda VG, Miller DR, Hofer TP, Holleman RG, Klamerus ML, Kerr EA. Accounting for clinical action reduces estimates of gender disparities in lipid management for diabetic veterans. J Gen Intern Med. 2013;28 Suppl 2:S529-535.23807061
261 Wallin MT, Culpepper WJ, Coffman P, . The Gulf War era multiple sclerosis cohort: Age and incidence rates by race, sex and service. Brain. 2012;135(Pt 6):1778-1785.22628389
262 Al Mohajer M, Musher DM, Minard CG, Darouiche RO. Clinical significance of staphylococcus aureus bacteriuria at a tertiary care hospital. Scand J Infect Dis. 2013;45(9):688-695.23808717
263 Alazzeh A, Cooper MM, Bailey B, Youssef DA, Manning T, Peiris AN. Vitamin D status and monitoring in female veterans. Women Health. 2015;55(4):367-377.25866148
264 Anger JT, Saigal CS, Wang M, Yano EM, Urologic Diseases in America P. Urologic disease burden in the United States: Veteran users of Department of Veterans Affairs healthcare. Urology. 2008;72(1):37-41.18342928
265 Bair MJ, Matthias MS, Nyland KA, . Barriers and facilitators to chronic pain self-management: A qualitative study of primary care patients with comorbid musculoskeletal pain and depression. Pain Med. 2009;10(7):1280-1290.19818038
266 Barnett PG, Hamlett-Berry K, Sung HY, Max W. Health care expenditures attributable to smoking in military veterans. Nicotine Tob Res. 2015;17(5):586-591.25239960
267 Baughman KR, Bourguet CC, Ober SK. Gender differences in the association between antidepressant use and restless legs syndrome. Mov Disord. 2009;24(7):1054-1059.19353713
268 Carlson KF, Taylor BC, Hagel EM, Cutting A, Kerns R, Sayer NA. Headache diagnoses among Iraq and Afghanistan War veterans enrolled in VA: A gender comparison. Headache. 2013;53(10):1573-1582.24102376
269 Denke L, Barnes DM. An ethnography of chronic pain in veteran enlisted women. Pain Manag Nurs. 2013;14(4):e189-195.24315272
270 Dodge HS, Ekhator NN, Jefferson-Wilson L, . Cigarette smokers have reduced risk for post-dural puncture headache. Pain Physician. 2013;16(1):E25-30.23340541
271 Driscoll MA, Higgins DM, Seng EK, . Trauma, social support, family conflict, and chronic pain in recent service veterans: Does gender matter? Pain Med. 2015;16(6):1101-1111.25930005
272 Farmer MM, Rose DE, Riopelle D, Lanto AB, Yano EM. Gender differences in smoking and smoking cessation treatment: An examination of the organizational features related to care. Womens Health Issues. 2011;21(4 Suppl):S182-189.21724139
273 Graham DP, Savas L, White D, . Irritable bowel syndrome symptoms and health related quality of life in female veterans. Aliment Pharmacol Ther. 2010;31(2):261-273.19814746
274 Groessl EJ, Weingart KR, Johnson N, Baxi S. The benefits of yoga for women veterans with chronic low back pain. J Altern Complement Med. 2012;18(9):832-838.22812905
275 Haskell SG, Brandt CA, Krebs EE, Skanderson M, Kerns RD, Goulet JL. Pain among veterans of Operations Enduring Freedom and Iraqi Freedom: Do women and men differ? Pain Med. 2009;10(7):1167-1173.19818028
276 Khan N, Abbas AM, Almukhtar RM, Cole EB, Khan AN. Adherence and efficacy of screening for low bone mineral density among ulcerative colitis patients treated with corticosteroids. Am J Gastroenterol. 2014;109(4):572-578.24469613
277 Maciejewski ML, Livingston EH, Kahwati LC, Henderson WG, Kavee AL, Arterburn DE. Discontinuation of diabetes and lipid-lowering medications after bariatric surgery at Veterans Affairs Medical Centers. Surg Obes Relat Dis. 2010;6(6):601-607.20965791
278 Maciejewski ML, Livingston EH, Smith VA, . Survival among high-risk patients after bariatric surgery. JAMA. 2011;305(23):2419-2426.21666276
279 Murphy LB, Helmick CG, Allen KD, . Arthritis among veterans - United States, 2011-2013. MMWR Morb Mortal Wkly Rep. 2014;63(44):999-1003.25375071
280 Oliva EM, Midboe AM, Lewis ET, . Sex differences in chronic pain management practices for patients receiving opioids from the Veterans Health Administration. Pain Med. 2015;16(1):112-118.25039721
281 Rivera JC, Krueger CA, Johnson AE. Female combat amputees have higher rates of posttraumatic stress disorder disability. US Army Med Dep J. 2015:74-79.26101909
282 Rohde NN, Baca CB, Van Cott AC, Parko KL, Amuan ME, Pugh MJ. Antiepileptic drug prescribing patterns in Iraq and Afghanistan War veterans with epilepsy. Epilepsy Behav. 2015;46:133-139.25911209
283 Shibuya N, Jupiter DC, Ciliberti LJ, Jr., VanBuren V, La Fontaine J. Prevalence of podiatric medical problems in veterans versus nonveterans. J Am Podiatr Med Assoc. 2011;101(4):323-330.21817001
284 Smylie AL, Broderick G, Fernandes H, . A comparison of sex-specific immune signatures in Gulf War illness and chronic fatigue syndrome. BMC Immunol. 2013;14:29.23800166
285 Wallin MT, Kurtzke JF, Culpepper WJ, . Multiple sclerosis in Gulf War era veterans. 2. Military deployment and risk of multiple sclerosis in the first Gulf War. Neuroepidemiology. 2014;42(4):226-234.24862835
286 Weimer MB, Macey TA, Nicolaidis C, Dobscha SK, Duckart JP, Morasco BJ. Sex differences in the medical care of VA patients with chronic non-cancer pain. Pain Med. 2013;14(12):1839-1847.23802846
287 Weisskopf MG, Cudkowicz ME, Johnson N. Military service and amyotrophic lateral sclerosis in a population-based cohort. Epidemiology. 2015;26(6):831-838.26414854
288 Bastian L, Fish LJ, Gierisch JM, Stechuchak KM, Grambow SC, Keefe FJ. Impact of smoking cessation on subsequent pain intensity among chronically ill veterans enrolled in a smoking cessation trial. J Pain Symptom Mnage. 2015;50(6):822-829.
289 Baker LD, Frank LL, Foster-Schubert K, . Effects of aerobic exercise on mild cognitive impairment: A controlled trial. Arch Neurol. 2010;67(1):71-79.20065132
290 Davisson L, Warden M, Manivannan S, . Osteoporosis screening: Factors associated with bone mineral density testing of older women. J Womens Health. 2009;18(7):989-994.
291 Der-Martirosian C, Cordasco KM, Washington DL. Health-related quality of life and comorbidity among older women veterans in the United States. Qual Life Res. 2013;22(10):2749-2756.23653159
292 Friedlander AH, El-Saden SM, Aghazadehsanai N, Chang TI, Harada ND, Garrett NR. Association of calcified carotid atheromas visualized on panoramic images and aortic arch calcifications seen on chest radiographs of postmenopausal women. J Am Dent Assoc. 2014;145(4):345-351.24686967
293 Gerber MR, King MW, Pineles SL, . Hormone therapy use in women veterans accessing Veterans Health Administration care: A national cross-sectional study. J Gen Intern Med. 2015;30(2):169-175.25373833
294 Haskell SG, Bean-Mayberry B, Gordon K. Discontinuing postmenopausal hormone therapy: An observational study of tapering versus quitting cold turkey: Is there a difference in recurrence of menopausal symptoms? Menopause. 2009;16(3):494-499.19182695
295 Haskell SG, Bean-Mayberry B, Goulet JL, Skanderson M, Good CB, Justice AC. Determinants of hormone therapy discontinuation among female veterans nationally. Mil Med. 2008;173(1):91-96.18251338
296 LaFleur J, DuVall SL, Willson T, . Analysis of osteoporosis treatment patterns with bisphosphonates and outcomes among postmenopausal veterans. Bone. 2015;78:174-185.
297 Lavela SL, Etingen B, Louise-Bender Pape T. Caregiving experiences and health conditions of women veteran and non-veteran caregivers. Womens Health Issues. 2013;23(4):e225-232.23816152
298 Rimland D, Moanna A. Increasing incidence of herpes zoster among veterans. Clin Infect Dis. 2010;50(7):1000-1005.20178416
299 Rouen PA, Krein SL, Reame NE. Postmenopausal symptoms in female veterans with type 2 diabetes: Glucose control and symptom severity. J Womens Health. 2015;24(6):496-505.
300 Shibli-Rahhal A, Vaughan-Sarrazin MS, Richardson K, Cram P. Testing and treatment for osteoporosis following hip fracture in an integrated U.S. Healthcare delivery system. Osteoporos Int. 2011;22(12):2973-2980.21271339
301 Weitlauf JC, LaCroix AZ, Bird CE, . Prospective analysis of health and mortality risk in veteran and non-veteran participants in the women's health initiative. Womens Health Issues. 2015;25(6):649-657.26432346
302 Borrero S, Mor MK, Zhao X, McNeil M, Ibrahim S, Hayes P. Contraceptive care in the VA health care system. Contraception. 2012;85(6):580-588.22176794
303 Borrero S, Zhao X, Mor MK, Schwarz EB, Good CB, Gellad WF. Adherence to hormonal contraception among women veterans: Differences by race/ethnicity and contraceptive supply. Am J Obstet Gynecol. 2013;209(2):103.e101-111.23524170
304 Bukowinski AT, DeScisciolo C, Conlin AM, MA KR, Sevick CJ, Smith TC. Birth defects in infants born in 1998-2004 to men and women serving in the U.S. Military during the 1990-1991 Gulf War era. Birth Defects Res A Clin Mol Teratol. 2012;94(9):721-728.22903974
305 Callegari LS, Borrero S, Reiber GE, . Reproductive life planning in primary care: A qualitative study of women veterans' perceptions. Womens Health Issues. 2015;25(5):548-554.26123640
306 Goyal V, Mattocks K, Bimla Schwarz E, . Contraceptive provision in the VA healthcare system to women who report military sexual trauma. J Womens Health. 2014;23(9):740-745.
307 Gray KE, Katon JG, Callegari LS, Cordasco KM, Zephyrin LC. Gynecologists in the VA: Do they enhance availability of sex-specific services and policies in the emergency department? Med Care. 2015;53(4 Suppl 1):S76-80.25767980
308 Katon J, Cypel Y, Raza M, . Self-reported infertility among male and female veterans serving during Operation Enduring Freedom/Operation Iraqi Freedom. J Womens Health. 2014;23(2):175-183.
309 Katon J, Mattocks K, Zephyrin L, . Gestational diabetes and hypertensive disorders of pregnancy among women veterans deployed in service of operations in Afghanistan and Iraq. J Womens Health. 2014;23(10):792-800.
310 Katon J, Reiber G, Rose D, . VA location and structural factors associated with on-site availability of reproductive health services. J Gen Intern Med. 2013;28 Suppl 2:S591-597.23807070
311 Katon JG, Hoggatt KJ, Balasubramanian V, . Reproductive health diagnoses of women veterans using Department of Veterans Affairs health care. Med Care. 2015;53(4 Suppl 1):S63-67.25767978
312 Katon JG, Washington DL, Cordasco KM, Reiber GE, Yano EM, Zephyrin LC. Prenatal care for women veterans who use Department of Veterans Affairs health care. Womens Health Issues. 2015;25(4):377-381.25935821
313 Kazerooni R, Blake A, Thai J. Predictors of pregnancy in female veterans receiving a hormonal contraceptive pill, patch, or ring. Ann Pharmacother. 2015;49(12):1284-1290.26416948
314 Kazerooni R, Takizawa A, Vu K. Predictors of adherence to hormonal contraceptives in a female veteran population. Contraception. 2014;89(4):292-298.24457062
315 Kazerooni R, Vu K, Takizawa A, Broadhead C, Morreale AP. Association of copayment and socioeconomic status with hormonal contraceptive adherence in a female veteran population. Womens Health Issues. 2014;24(2):e237-241.24533983
316 Lehavot K, Katon JG, Williams EC, . Sexual behaviors and sexually transmitted infections in a nationally representative sample of women veterans and nonveterans. J Womens Health. 2014;23(3):246-252.
317 Mattocks K, Kroll-Desrosiers A, Zephyrin L, . Infertility care among OEF/OIF/OND women veterans in the Department of Veterans Affairs. Med Care. 2015;53(4 Suppl 1):S68-75.25767979
318 Mattocks KM, Frayne S, Phibbs CS, . Five-year trends in women veterans' use of VA maternity benefits, 2008-2012. Womens Health Issues. 2014;24(1):e37-42.24439945
319 Mattocks KM, Nikolajski C, Haskell S, . Women veterans' reproductive health preferences and experiences: A focus group analysis. Womens Health Issues. 2011;21(2):124-129.21353978
320 Ryan GL, Mengeling MA, Booth BM, Torner JC, Syrop CH, Sadler AG. Voluntary and involuntary childlessness in female veterans: Associations with sexual assault. Fertil Steril. 2014;102(2):539-547.24875400
321 Sadler AG, Mengeling MA, Fraley SS, Torner JC, Booth BM. Correlates of sexual functioning in women veterans: Mental health, gynecologic health, health status, and sexual assault history. Int J Sex Health. 2012;24(1):60-77.
322 Sadler AG, Mengeling MA, Syrop CH, Torner JC, Booth BM. Lifetime sexual assault and cervical cytologic abnormalities among military women. J Womens Health. 2011;20(11):1693-1701.
323 Schwarz EB, Longo LS, Zhao X, Stone RA, Cunningham F, Good CB. Provision of potentially teratogenic medications to female veterans of childbearing age. Med Care. 2010;48(9):834-842.20706159
324 Schwarz EB, Mattocks K, Brandt C, . Counseling of female veterans about risks of medication-induced birth defects. J Gen Intern Med. 2013;28 Suppl 2:S598-603.23807071
325 Womack JA, Scotch M, Leung SN, . Use of structured and unstructured data to identify contraceptive use in women veterans. Perspect Health Inf Manag. Summer 2013 2013:1-15.
326 Bean-Mayberry B, Yano EM, Mor MK, Bayliss NK, Xu X, Fine MJ. Does sex influence immunization status for influenza and pneumonia in older veterans? J Am Geriatr Soc. 2009;57(8):1427-1432.19515114
327 Bryan TJ, Estrada CA, Castiglioni A, Snyder ED. Impact of an educational intervention on provider knowledge, attitudes, and comfort level regarding counseling women ages 40-49 about breast cancer screening. J Multidiscip Healthc. 2015;8:209-216.25999731
328 Chou AF, Rose DE, Farmer M, Canelo I, Yano EM. Organizational factors affecting the likelihood of cancer screening among VA patients. Med Care. 2015;53(12):1040-1049.26569643
329 del Junco DJ, Vernon SW, Coan SP, . Promoting regular mammography screening i. A systematic assessment of validity in a randomized trial. J Natl Cancer Inst. 2008;100(5):333-346.18314473
330 Forbus L, Kelly UA. Screening for obstructive sleep apnea in veterans seeking treatment of posttraumatic stress disorder. ANS Adv Nurs Sci. 2015;38(4):298-305.26517341
331 Gellad ZF, Stechuchak KM, Fisher DA, . Longitudinal adherence to fecal occult blood testing impacts colorectal cancer screening quality. Am J Gastroenterol. 2011;106(6):1125-1134.21304501
332 Griffin JM, Burgess D, Vernon SW, . Are gender differences in colorectal cancer screening rates due to differences in self-reporting? Prev Med. 2009;49(5):436-441.19765609
333 Haskell SG, Gordon KS, Mattocks K, . Gender differences in rates of depression, PTSD, pain, obesity, and military sexual trauma among Connecticut war veterans of Iraq and Afghanistan. J Womens Health. 2010;19(2):267-271.
334 Lairson DR, Chan W, Chang YC, del Junco DJ, Vernon SW. Cost-effectiveness of targeted versus tailored interventions to promote mammography screening among women military veterans in the United States. Eval Program Plann. 2011;34(2):97-104.20810168
335 Littman AJ, Koepsell TD, Forsberg CW, Haselkorn JK, Boyko EJ. Preventive services in veterans in relation to disability. J Rehabil Res Dev. 2012;49(3):339-350.22773194
336 Rivera CM, Copeland LA, McNeal CJ, Mortensen EM, Pugh MJ, MacCarthy DJ. Use of health care system-supplied aspirin by veterans with postoperative heart attack or unstable angina. Am J Med Sci. 2015;350(4):263-267.26351774
337 Ross JS, Keyhani S, Keenan PS, . Dual use of Veterans Affairs services and use of recommended ambulatory care. Med Care. 2008;46(3):309-316.18388846
338 Vernon SW, del Junco DJ, Tiro JA, . Promoting regular mammography screening ii. Results from a randomized controlled trial in US women veterans. J Natl Cancer Inst. 2008;100(5):347-358.18314474
339 Yancy WS, Jr., McDuffie JR, Stechuchak KM, . Obesity and receipt of clinical preventive services in veterans. Obesity. 2010;18(9):1827-1835.20203629
340 Yee EF, White R, Lee SJ, . Mental illness: Is there an association with cancer screening among women veterans? Womens Health Issues. 2011;21(4 Suppl):S195-202.21724141
341 Federman DG, Kravetz JD, Ma F, Kirsner RS. Patient gender affects skin cancer screening practices and attitudes among veterans. South Med J. 2008;101(5):513-518.18414179
342 Murphy CC, Vernon SW, Diamond PM, Tiro JA. Competitive testing of health behavior theories: How do benefits, barriers, subjective norm, and intention influence mammography behavior? Ann Behav Med. 2014;47(1):120-129.23868613
343 Bastian LA, Trentalange M, Murphy TE, . Association between women veterans' experiences with VA outpatient health care and designation as a women's health provider in primary care clinics. Womens Health Issues. 2014;24(6):605-612.25442706
344 Bean-Mayberry B, Bastian L, Trentalange M, . Associations between provider designation and female-specific cancer screening in women veterans. Med Care. 2015;53(4 Suppl 1):S47-54.25767975
345 Bergman AA, Frankel RM, Hamilton AB, Yano EM. Challenges with delivering gender-specific and comprehensive primary care to women veterans. Womens Health Issues. 2015;25(1):28-34.25530547
346 Cordasco KM, Zephyrin LC, Kessler CS, . An inventory of VHA emergency departments' resources and processes for caring for women. J Gen Intern Med. 2013;28 Suppl 2:S583-590.23807069
347 Cordasco KM, Zuchowski JL, Hamilton AB, . Early lessons learned in implementing a women's health educational and virtual consultation program in VA. Med Care. 2015;53(4 Suppl 1):S88-92.25767983
348 deKleijn M, Lagro-Janssen AL, Canelo I, Yano EM. Creating a roadmap for delivering gender-sensitive comprehensive care for women veterans: Results of a national expert panel. Med Care. 2015;53(4 Suppl 1):S156-164.25767971
349 Johnson-Lawrence VD, Szymanski BR, Zivin K, McCarthy JF, Valenstein M, Pfeiffer PN. Primary care-mental health integration programs in the Veterans Affairs health system serve a different patient population than specialty mental health clinics. Prim Care Companion CNS Disord. 2012;14(3).
350 Kauth MR, Shipherd JC, Lindsay JA, Kirsh S, Knapp H, Matza L. Teleconsultation and training of VHA providers on transgender care: Implementation of a multisite hub system. Telemed J E Health. 2015;21(12):1012-1018.26171641
351 Kilbourne AM, Pirraglia PA, Lai Z, . Quality of general medical care among patients with serious mental illness: Does colocation of services matter? Psychiatr Serv. 2011;62(8):922-928.21807832
352 Kimerling R, Bastian LA, Bean-Mayberry BA, . Patient-centered mental health care for female veterans. Psychiatr Serv. 2015;66(2):155-162.25642611
353 MacGregor C, Hamilton AB, Oishi SM, Yano EM. Description, development, and philosophies of mental health service delivery for female veterans in the VA: A qualitative study. Womens Health Issues. 2011;21(4 Suppl):S138-144.21724133
354 Mengeling MA, Sadler AG, Torner J, Booth BM. Evolving comprehensive VA women's health care: Patient characteristics, needs, and preferences. Womens Health Issues. 2011;21(4 Suppl):S120-129.21724131
355 Moin T, Ertl K, Schneider J, . Women veterans' experience with a web-based diabetes prevention program: A qualitative study to inform future practice. J Med Internet Res. 2015;17(5):e127.26006697
356 Oishi SM, Rose DE, Washington DL, MacGregor C, Bean-Mayberry B, Yano EM. National variations in VA mental health care for women veterans. Womens Health Issues. 2011;21(4 Suppl):S130-137.21724132
357 O'Toole TP, Pirraglia PA, Dosa D, . Building care systems to improve access for high-risk and vulnerable veteran populations. J Gen Intern Med. 2011;26 Suppl 2:683-688.
358 Sherman MD, Kauth MR, Shipherd JC, Street RL, Jr. Communication between VA providers and sexual and gender minority veterans: A pilot study. Psychol Serv. 2014;11(2):235-242.24588107
359 Tsai J, David DH, Edens EL, Crutchfield A. Considering child care and parenting needs in Veterans Affairs mental health services. Eval Program Plann. 2013;39:19-22.23570988
360 Tsai J, Mota NP, Pietrzak RH. U.S. Female veterans who do and do not rely on VA health care: Needs and barriers to mental health treatment. Psychiatr Serv. 2015;66(11):1200-1206.26174948
361 Vigil JM, Alcock J, Coulombe P, . Ethnic disparities in emergency severity index scores among U.S. Veteran's affairs emergency department patients. PLoS One. 2015;10(5):e0126792.26024515
362 Vogt DS, Barry AA, King LA. Toward gender-aware health care: Evaluation of an intervention to enhance care for female patients in the VA setting. J Health Psychol. 2008;13(5):624-638.18519436
363 Wagner C, Dichter ME, Mattocks K. Women veterans' pathways to and perspectives on Veterans Affairs health care. Womens Health Issues. 2015;25(6):658-665.26341566
364 Washington DL, Bean-Mayberry B, Hamilton AB, Cordasco KM, Yano EM. Women veterans' healthcare delivery preferences and use by military service era: Findings from the national survey of women veterans. J Gen Intern Med. 2013;28 Suppl 2:S571-576.23807067
365 Washington DL, Bean-Mayberry B, Mitchell MN, Riopelle D, Yano EM. Tailoring VA primary care to women veterans: Association with patient-rated quality and satisfaction. Womens Health Issues. 2011;21(4 Suppl):S112-119.21724130
366 Washington DL, Farmer MM, Mor SS, Canning M, Yano EM. Assessment of the healthcare needs and barriers to VA use experienced by women veterans: Findings from the national survey of women veterans. Med Care. 2015;53(4 Suppl 1):S23-31.25767972
367 Whitehead AM, Czarnogorski M, Wright SM, Hayes PM, Haskell SG. Improving trends in gender disparities in the Department of Veterans Affairs: 2008-2013. Am J Public Health. 2014;104 Suppl 4:S529-531.25100416
368 Hausmann LR, Gao S, Mor MK, Schaefer JH, Jr., Fine MJ. Patterns of sex and racial/ethnic differences in patient health care experiences in US Veterans Affairs hospitals. Med Care. 2014;52(4):328-335.24848206
369 Kimerling R, Pavao J, Greene L, . Access to mental health care among women veterans: Is VA meeting women's needs? Med Care. 2015;53(4 Suppl 1):S97-S104.25767985
370 Martinez ME, Kearney DJ, Simpson T, Felleman BI, Bernardi N, Sayre G. Challenges to enrollment and participation in mindfulness-based stress reduction among veterans: A qualitative study. J Altern Complement Med. 2015;21(7):409-421.26133205
371 Sambamoorthi U, Bean-Mayberry B, Findley PA, Yano EM, Banerjea R. Organization of care and diagnosed depression among women veterans. Am J Manag Care. 2010;16(9):657-665.20873953
372 Seal KH, Cohen G, Bertenthal D, Cohen BE, Maguen S, Daley A. Reducing barriers to mental health and social services for Iraq and Afghanistan veterans: Outcomes of an integrated primary care clinic. J Gen Intern Med. 2011;26(10):1160-1167.21647750
373 Brooks E, Dailey N, Bair B, Shore J. Rural women veterans demographic report: Defining VA users' health and health care access in rural areas. J Rural Health. 2014;30(2):146-152.24689540
374 Ohl M, Lund B, Belperio PS, . Rural residence and adoption of a novel HIV therapy in a national, equal-access healthcare system. AIDS Behav. 2013;17(1):250-259.22205324
375 Tan G, Teo I, Srivastava D, . Improving access to care for women veterans suffering from chronic pain and depression associated with trauma. Pain Med. 2013;14(7):1010-1020.23659470
376 Delcher C, Wang Y, Maldonado-Molina M. Trends in financial barriers to medical care for women veterans, 2003-2004 and 2009-2010. Prev Chronic Dis. 2013;10:E171.24157074
377 Duggal M, Goulet JL, Womack J, . Comparison of outpatient health care utilization among returning women and men veterans from Afghanistan and Iraq. BMC Health Serv Res. 2010;10:175.20565985
378 Fox AB, Meyer EC, Vogt D. Attitudes about the VA health-care setting, mental illness, and mental health treatment and their relationship with VA mental health service use among female and male OEF/OIF veterans. Psychol Serv. 2015;12(1):49-58.25365245
379 Friedman SA, Frayne SM, Berg E, . Travel time and attrition from VHA care among women veterans: How far is too far? Med Care. 2015;53(4 Suppl 1):S15-22.25767970
380 Friedman SA, Phibbs CS, Schmitt SK, Hayes PM, Herrera L, Frayne SM. New women veterans in the VHA: A longitudinal profile. Womens Health Issues. 2011;21(4 Suppl):S103-111.21724129
381 Grossbard JR, Lehavot K, Hoerster KD, Jakupcak M, Seal KH, Simpson TL. Relationships among veteran status, gender, and key health indicators in a national young adult sample. Psychiatr Serv. 2013;64(6):547-553.23450338
382 Hamilton AB, Frayne SM, Cordasco KM, Washington DL. Factors related to attrition from VA healthcare use: Findings from the national survey of women veterans. J Gen Intern Med. 2013;28 Suppl 2:S510-516.23807058
383 Hamilton AB, Poza I, Hines V, Washington DL. Barriers to psychosocial services among homeless women veterans. J Soc Work Pract Addict. 2012;12(1):52-68.26617471
384 Kauth MR, Shipherd JC, Lindsay J, Blosnich JR, Brown GR, Jones KT. Access to care for transgender veterans in the Veterans Health Administration: 2006-2013. Am J Public Health. 2014;104 Suppl 4:S532-534.25100417
385 Lehavot K, Der-Martirosian C, Simpson TL, Sadler AG, Washington DL. Barriers to care for women veterans with posttraumatic stress disorder and depressive symptoms. Psychol Serv. 2013;10(2):203-212.23730964
386 McCarthy JF, Valenstein M, Dixon L, Visnic S, Blow FC, Slade E. Initiation of assertive community treatment among veterans with serious mental illness: Client and program factors. Psychiatr Serv. 2009;60(2):196-201.19176413
387 Owens GP, Herrera CJ, Whitesell AA. A preliminary investigation of mental health needs and barriers to mental health care for female veterans of Iraq and Afghanistan. Traumatology. 2009;15(2):31-37.
388 Shen C, Sambamoorthi U. Associations between health-related quality of life and financial barriers to care among women veterans and women non-veterans. Women Health. 2012;52(1):1-17.22324355
389 Shen Y, Hendricks A, Wang F, Gardner J, Kazis LE. The impact of private insurance coverage on veterans' use of VA care: Insurance and selection effects. Health Serv Res. Feb 2008;43(1 Pt 1):267-286.18211529
390 Shipherd JC, Mizock L, Maguen S, Green KE. Male-to-female transgender veterans and VA health care utilization. Int J Sex Health. 2012;24(1):78-87.
391 Simpson TL, Balsam KF, Cochran BN, Lehavot K, Gold SD. Veterans administration health care utilization among sexual minority veterans. Psychol Serv. 2013;10(2):223-232.23730965
392 Washington DL, Bean-Mayberry B, Riopelle D, Yano EM. Access to care for women veterans: Delayed healthcare and unmet need. J Gen Intern Med. 2011;26 Suppl 2:655-661.21989618
393 Di Leone BA, Vogt D, Gradus JL, Street AE, Giasson HL, Resick PA. Predictors of mental health care use among male and female veterans deployed in support of the wars in Afghanistan and Iraq. Psychol Serv. 2013;10(2):145-151.23730960
394 Elbogen EB, Wagner HR, Johnson SC, . Are Iraq and Afghanistan veterans using mental health services? New data from a national random-sample survey. Psychiatr Serv. 2013;64(2):134-141.23475498
395 Hundt NE, Barrera TL, Mott JM, . Predisposing, enabling, and need factors as predictors of low and high psychotherapy utilization in veterans. Psychol Serv. Aug 2014;11(3):281-289.24841513
396 Koo KH, Madden E, Maguen S. Race-ethnicity and gender differences in VA health care service utilization among U.S. Veterans of recent conflicts. Psychiatr Serv. 2015;66(5):507-513.25588415
397 Kramer BJ, Jouldjian S, Washington DL, Harker JO, Saliba D, Yano EM. Health care for american indian and alaska native women. Womens Health Issues. 2009;19(2):135-143.19272564
398 Reinhard MJ, Nassif TH, Bloeser K, . Cam utilization among OEF/OIF veterans: Findings from the national health study for a new generation of US veterans. Med Care. 2014;52(12 Suppl 5):S45-49.
399 West AN, Lee PW. Associations between childbirth and women veterans' VA and non-VA hospitalizations for major diagnostic categories. Mil Med. 2013;178(11):1250-1255.24183775
400 Afari N, Pittman J, Floto E, . Differential impact of combat on postdeployment symptoms in female and male veterans of Iraq and Afghanistan. Mil Med. 2015;180(3):296-303.25735020
401 Burkhart L, Hogan N. Being a female veteran: A grounded theory of coping with transitions. Soc Work Ment Health. 2015;13(2):108-127.25745366
402 Eisen SV, Schultz MR, Vogt D, . Mental and physical health status and alcohol and drug use following return from deployment to Iraq or Afghanistan. Am J Public Health. 2012;102 Suppl 1:S66-73.22390605
403 Haskell SG, Mattocks K, Goulet JL, . The burden of illness in the first year home: Do male and female VA users differ in health conditions and healthcare utilization. Womens Health Issues. 2011;21(1):92-97.21185994
404 Haskell SG, Ning Y, Krebs E, . Prevalence of painful musculoskeletal conditions in female and male veterans in 7 years after return from deployment in Operation Enduring Freedom/Operation Iraqi Freedom. Clin J Pain. 2012;28(2):163-167.21677563
405 Hoglund MW, Schwartz RM. Mental health in deployed and nondeployed veteran men and women in comparison with their civilian counterparts. Mil Med. 2014;179(1):19-25.
406 Kachadourian LK, Smith BN, Taft CT, Vogt D. The impact of infidelity on combat-exposed service members. J Trauma Stress. 2015;28(5):418-425.26397362
407 Kang HK, Cypel Y, Kilbourne AM, . Healthviews: Mortality study of female US Vietnam era veterans, 1965-2010. Am J Epidemiol. 2014;179(6):721-730.24488510
408 Katz LS, Cojucar G, Davenport CT, Pedram C, Lindl C. Post-deployment readjustment inventory: Reliability, validity, and gender differences. Mil Psychol. 2010;22(1):41-56.
409 Koenig CJ, Maguen S, Monroy JD, Mayott L, Seal KH. Facilitating culture-centered communication between health care providers and veterans transitioning from military deployment to civilian life. Patient Educ Couns. 2014;95(3):414-420.24742536
410 Leslie DL, Goulet J, Skanderson M, Mattocks K, Haskell S, Brandt C. VA health care utilization and costs among male and female veterans in the year after service in Afghanistan and Iraq. Mil Med. 2011;176(3):265-269.21456351
411 Mankowski M, Haskell SG, Brandt C, Mattocks KM. Social support throughout the deployment cycle for women veterans returning from Iraq and Afghanistan. Soc Work Health Care. 2015;54(4):287-306.25905763
412 Rivera JC, Hylden CM, Johnson AE. Disability after deployment injury: Are women and men service members different? Clin Orthop Relat Res. 2015;473(8):2448-2454.25666145
413 Sayer NA, Noorbaloochi S, Frazier PA, . Randomized controlled trial of online expressive writing to address readjustment difficulties among U.S. Afghanistan and Iraq War veterans. J Trauma Stress. 2015;28(5):381-390.26467326
414 Street AE, Gradus JL, Giasson HL, Vogt D, Resick PA. Gender differences among veterans deployed in support of the wars in Afghanistan and Iraq. J Gen Intern Med. 2013;28 Suppl 2:S556-562.23807065
415 Villagran M, Ledford CJ, Canzona MR. Women's health identities in the transition from military member to service veteran. J Health Commun. 2015;20(10):1125-1132.26305865
416 Wang JM, Lee LO, Spiro A, 3rd. Gender differences in the impact of warfare exposure on self-rated health. Womens Health Issues. 2015;25(1):35-41.25442366
417 Maguen S, Madden E, Cohen BE, Bertenthal D, Seal KH. Time to treatment among veterans of conflicts in Iraq and Afghanistan with psychiatric diagnoses. Psychiatr Serv. 2012;63(12):1206-1212.23070131
418 Blackstock OJ, Haskell SG, Brandt CA, Desai RA. Gender and the use of Veterans Health Administration homeless services programs among Iraq/Afghanistan veterans. Med Care. 2012;50(4):347-352.22422055
419 Hamilton AB, Poza I, Washington DL. “Homelessness and trauma go hand-in-hand”: Pathways to homelessness among women veterans. Womens Health Issues. 2011;21(4):S203-209.21724142
420 Harpaz-Rotem I, Rosenheck RA, Desai R. Residential treatment for homeless female veterans with psychiatric and substance use disorders: Effect on 1-year clinical outcomes. J Rehabil Res Dev. 2011;48(8):891-899.22068368
421 Metraux S, Clegg LX, Daigh JD, Culhane DP, Kane V. Risk factors for becoming homeless among a cohort of veterans who served in the era of the Iraq and Afghanistan conflicts. Am J Public Health. Dec 2013;103 Suppl 2:S255-261.24148066
422 Montgomery AE, Byrne TH. Services utilization among recently homeless veterans: A gender-based comparison. Mil Med. 2014;179(3):236-239.24594455
423 Tsai J, Kasprow WJ, Kane V, Rosenheck RA. National comparison of literally homeless male and female VA service users: Entry characteristics, clinical needs, and service patterns. Womens Health Issues. 2014;24(1):e29-35.24342077
424 Tsai J, Pietrzak RH, Rosenheck RA. Homeless veterans who served in Iraq and Afghanistan: Gender differences, combat exposure, and comparisons with previous cohorts of homeless veterans. Adm Policy Ment Health. Sep 2013;40(5):400-405.22824909
425 Tsai J, Rosenheck RA, Kane V. Homeless female U.S. Veterans in a national supported housing program: Comparison of individual characteristics and outcomes with male veterans. Psychol Serv. 2014;11(3):309-316.24730678
426 Tsai J, Rosenheck RA, Kasprow WJ, Kane V. Characteristics and use of services among literally homeless and unstably housed U.S. Veterans with custody of minor children. Psychiatr Serv. 2015;66(10):1083-1090.25975888
427 Tsai J, Rosenheck RA, McGuire JF. Comparison of outcomes of homeless female and male veterans in transitional housing. Community Ment Health J. 2012;48(6):705-710.22294507
428 Washington DL, Yano EM, McGuire J, Hines V, Lee M, Gelberg L. Risk factors for homelessness among women veterans. J Health Care Poor Underserved. 2010;21(1):82-91.
429 Montgomery AE, Dichter ME, Thomasson AM, Fu X, Roberts CB. Demographic characteristics associated with homelessness and risk among female and male veterans accessing VHA outpatient care. Womens Health Issues. 2015;25(1):42-48.25498763
430 Allore HG, Ning Y, Brandt CA, Goulet JL. Accounting for the hierarchical structure in Veterans Health Administration data: Differences in healthcare utilization between men and women veterans. Int J Stat Med Res. 2013;2(2):94-103.24910720
431 Blosnich J, Foynes MM, Shipherd JC. Health disparities among sexual minority women veterans. J Womens Health. 2013;22(7):631-636.
432 Cypel Y, Kang H. Mortality patterns among women Vietnam-era veterans: Results of a retrospective cohort study. Ann Epidemiol. 2008;18(3):244-252.18280922
433 Hamilton AB, Williams L, Washington DL. Military and mental health correlates of unemployment in a national sample of women veterans. Med Care. 2015;53(4 Suppl 1):S32-38.25767973
434 Heslin KC, Gin JL, Afable MK, Ricci K, Dobalian A. Personal medication preparedness among veteran and nonveteran men and women in the california population. Prehosp Disaster Med. 2013;28(4):359-366.23731616
435 Lehavot K, Hoerster KD, Nelson KM, Jakupcak M, Simpson TL. Health indicators for military, veteran, and civilian women. Am J Prev Med. 2012;42(5):473-480.22516487
436 Linsky A, Simon SR, Bokhour B. Patient perceptions of proactive medication discontinuation. Patient Educ Couns. 2015;98(2):220-225.25435516
437 Savas LS, del Junco DJ, Bastian LA, Vernon SW. Mortality ascertainment of women veterans: A comparison of sources of vital status information, 1979-2002. Med Care. 2009;47(1):125-128.19106741
438 Yoon J, Scott JY, Phibbs CS, Frayne SM. Trends in rates and attributable costs of conditions among female VA patients, 2000 and 2008. Womens Health Issues. 2012;22(3):e337-344.22555220
439 Frayne SM, Yano EM, Nguyen VQ, . Gender disparities in Veterans Health Administration care: Importance of accounting for veteran status. Med Care. 2008;46(5):549-553.18438204
440 Schnurr PP, Friedman MJ, Engel CC, . Cognitive behavioral thearpy for posttraumatic stress disorder in women: A randomized controlled trial. JAMA. 2007;297(8):820-830.17327524
441 Cordasco KM, Huynh AK, Zephyrin L, . Building capacity in VA to provide emergency gynecology services for women. Med Care. 2015;53(4 Suppl 1):S81-87.25767982
442 Yano E, Frayne S (eds). Health and health care of women veterans and women in the military: Research informing evidence-based practice and policy. Womens Health Issues. 2011;21(4, Suppl).
443 Bastian LA, Bosworth HB, Washington DL, Yano EM (eds). Women veterans health and health care. J Gen Intern Med. 2013;28(Suppl 2).
444 Bastian LA, Mattocks KM, Bean-Mayberry B, . (eds). Women veteran's health and health care. Med Care. 2015;53(Suppl 1).
445 Yano EM, Bastian LA, Bean-Mayberry B, . Using research to transform care for women veterans: Advancing the resarch agenda and enhancing research-clinical partnerships. Womens Health Issues. 2011;21-4S:S73-S83.
446 Rohrer LD, Gierisch JM, Fish LJ, Blakeney JK, Bastian LA. A five-step guide for moving from observational studies to interventional research for women veterans. Womens Health Issues. 2011;21(4 Suppl):S98-102.21724150
447 Bastian LA, Bosworth HB, Washington DL, Yano EM. Setting the stage: Research to inform interventions, practice and policy to improve women veterans' health and health care. J Gen Intern Med. 2013;28(Suppl 2):491-494.
448 US Department of Health and Human Services, National Institutes of Health, Office of Research on Women's Health. Moving into the future with new dimensions and strategies: A vision for 2020 for women's health research. Strategic plan. (NIH Publication No. 10-7606) Bethesda, MD: National Institutes of Health, 2010.
449 Schulz KF, Altman DG, D. M. CONSORT 2010 statement: Updated guidelines for reporting parallel group randomized trials. Ann Intern Med. 2010;152(1):1-8.19949136
450 von Elm E, Altman DG, Egger M, Pocock SJ, Gotzsche PC, Vandenbroucke JP. The strengthening the reporting of observational studies in epidemiology (STROBE) statement: Guidelines for reporting observational studies. J Clin Epidemiol. 2008;61(4):344-349.18313558
451 Institute of Medicine. Women's health research: Progress, pitfalls, and promise. Washington, DC: National Academies Press, 2010.
452 Institute of Medicine. Sex-specific reporting of scientific research: A workshop summary. Washington, DC: National Academies Press, 2012.
453 Conard PL, Sauls DJ. Deployment and PTSD in the female combat veteran: A systematic review. Nurs Forum. 2014;49(1):1-10.24456548
454 Crum-Cianflone NF, Jacobson I. Gender differences of postdeployment post-traumatic stress disorder among service members and veterans of the Iraq and Afghanistan conflicts. Epidemiol Rev. 2014;36(1):5-18.23988441
455 Middleton K, Craig CD. A systematic literature review of PTSD among female veterans from 1990 to 2010. Social Work in Mental Health. 2012;10(3):233-252.
456 Chapman SL, Wu LT. Suicide and substance use among female veterans: A need for research. Drug Alcohol Depend. 2014;136:1-10.24315571
457 Hoggatt KJ, Jamison AL, Lehavot K, Cucciare MA, Timko C, Simpson TL. Alcohol and drug misuse, abuse, and dependence in women veterans. Epidemiol Rev. 2015;37:23-37.25608962
458 Runnals JJ, Garovoy N, McCutcheon SJ, . Systematic review of women veterans' mental health. Womens Health Issues. 2014;24(5):485-502.25213742
459 Bielawski MP, Goldstein KM, Mattocks KM, Bean-Mayberry B, Yano EM, Bastian LA. Improving care of chronic conditions for women veterans: Identifying opportunities for comparative effectiveness research. J Comp Eff Res. 2014;3(2):155-166.24645689
460 Zaleski, K.L. and L.S. Katz, Alice in wonderland: Exploring the experiences of female service members with a pregnancy resulting from rape. Social Work in Mental Health, 2014. 12(5-6): p. 391-410.
461 Backus, L.I., ., Impact of race/ethnicity and gender on HCV screening and prevalence among US veterans in Department of Veterans Affairs Care. American journal of public health, 2014. 104(S4): p. S555-S561.25100421
462 Wilmoth, J.M., A.S. London, and W.M. Parker, Sex differences in the relationship between military service status and functional limitations and disabilities. Population Research and Policy Review, 2011. 30(3): p. 333-354.