# METHODS

## TOPIC DEVELOPMENT

This topic was nominated by Ruth Klap, PhD, Program Manager of the VA Women's Health Research Consortium, VA HSR&D Center for the Study of Healthcare Innovation, Implementation on behalf of the VA Women's Health Services Office of Patient Care Services and the VA Women's Health Research Network. This review updates the Systematic Review of Women Veterans Health Research 2004-2008.^2^

## SEARCH STRATEGY

We searched MEDLINE (Ovid), CINAHL, and the HSR&D database for articles published from 2008 to December 2015. Our search was limited to studies enrolling adults and published in the English language. The search included the MeSH terms Women; Women's Health; Women's Health Services; Veterans; Veterans' Health; and Hospitals, Veterans. The full search strategy is presented in Appendix A. We also obtained additional articles by reviewing references lists of relevant systematic reviews identified from our literature search.

## STUDY SELECTION

Abstracts (2,276) were independently reviewed by a trained investigator or research associate. Given the number of abstracts and the minimal exclusion criteria, we chose to dual review a randomly selected 20% sample. Most abstracts were either excluded for very clear reasons (eg, our “VA” search criteria produced many studies related to “visual acuity” or “vertebral artery”) or else forwarded on for full-text review. Our exclusion criteria were as follows:

- Studies that were not relevant to health/ healthcare
- Studies that did not include women US Veterans
- Studies that only included active duty members of the military
- Case reports, letters, meeting abstracts, dissertations, editorials, narrative or systematic reviews, conceptual frameworks, and protocols
- Studies that included a very small proportion or absolute number of women Veterans
  - If total n < 100, excluded if proportion women < 10%
  - If total n = 100-1000, excluded if proportion women < 5%
  - If total n > 1000, accepted studies with any proportion of women
- Studies in which the proportion of Veterans is less than 75% and the article does not explicitly address the results of the study for Veterans
- Studies in which the proportion of women is less than 75% and the article does not explicitly address the results of the study for women

We excluded 1,092 references at the abstract stage. Full-text reports of the remaining 1,184 references identified as potentially eligible were obtained for further review using the exclusion criteria described above. Each article was independently reviewed by an investigator or research associate. A second reviewer independently reviewed a random 10% sample of studies and any additional studies that the original reviewer had questions about. If the 2 reviewers disagreed, a “group arbitration” system was used. We noted reasons for excluding a study at full-text review.

## DATA ABSTRACTION

We stratified our evidence map by 14 characteristics: 1) healthcare category, 2) study design, 3) number of participants, 4) proportion women, 5) population characteristics reported, 6) presence of special populations, 7) follow-up/duration, 8) research setting, 9) use of administrative database, 10) period of service, 11) Veteran engagement, 12) population, 13) outcomes reported, and 14) funding source. This information was extracted onto evidence tables by one investigator or research associate. For a randomly selected 10% sample of included studies, extraction was verified by a second researcher. Discrepancies were infrequent and when present with resolved by group discussion. To ensure consistency in selection of categories within a characteristic, an additional reviewer evaluated all included studies in categories that were inherently subjective (particularly “other” categories) and these were then double-reviewed by a second investigator. The principal investigator also performed additional checks while summarizing the findings by extracted categories.

A description of each of the study characteristics is presented at the start of the Results section.

## RISK OF BIAS ASSESSMENT

We did not rate the risk of bias of individual studies.

## DATA SYNTHESIS

We summarize studies by category of healthcare, study design, year of publication, sample size, proportion of women in the study sample, and funding source. We present our analysis as a broad literature map without commenting on the results or findings of individual studies.

## RATING THE BODY OF EVIDENCE

We did not rate the strength of evidence.

## PEER REVIEW

A draft version of this report was reviewed by content experts as well as clinical leadership. Reviewers' comments and our responses are presented in Appendix B and the report was modified as needed.