# INTRODUCTION

Women currently comprise approximately 10% of all living US Veterans. This proportion is projected to rise to 15% by 2035 as the number and proportion of women serving in the US Military continues to increase. The demographics and life experiences of women Veterans are distinct from those of both non-Veteran women and male Veterans. Consequently, women Veterans face multiple unique health and healthcare concerns that were historically underserved by the Veterans Health Administration (VHA). In the past several decades, the provision of high-quality, evidence-based, accessible healthcare for women Veterans has become an increasingly vital strategic priority within VA. A growing body of literature addresses the health and healthcare concerns of women Veterans. The VA Women's Health Research Network, established in 2010, seeks to systematically improve women's healthcare and reduce sex/gender disparities by filling critical knowledge gaps in the evidence base related to women Veterans' health and healthcare needs.

An early review identified the literature related to women Veterans' health published between 1978 and 2004,^1^ and a subsequent update evaluated the studies published between 2004 and 2008.^2^ For the current evidence map, we identified and examined the published literature related to women Veterans' health from 2008 through 2015. Topic stakeholders were interested in a broad overview of the growth and depth of research on health and healthcare for women Veterans. We framed our evidence map around healthcare topics of interest according to key study characteristics in order to facilitate planning of future VA research, policy and clinical activities in women Veterans' health. The population of interest was US women Veterans. We included all interventions, comparators, outcomes, and settings. Due to the breadth of research included, we did not extract, evaluate, or present study findings. We identified gaps in knowledge and future research needs in the broad field of women Veterans' health, one of the primary aims of an evidence map approach.^3^