# APPENDIX C SUMMARY TABLES AND FIGURES

Table 1 Overview of Studies by Healthcare Category

| | Mental Health | Medical | Long-term Care/Aging | Reproductive Health | Prevention/Screening | Healthcare Organization & | Rural Health | Access & Utilization | Post-deployment | Homelessness | Other | Total
Study Design | RCT/CCT | 4 | 0 | 1 | 0 | 1 | 1 | 0 | 0 | 1 | 0 | 0 | 8
Study Design | Secondary or sub-group analysis of RCT/CCT | 8 | 1 | 0 | 0 | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 12
Study Design | Observational (prospective cohort) | 13 | 5 | 1 | 0 | 0 | 1 | 1 | 0 | 0 | 2 | 0 | 23
Study Design | Observational (other) | 177 | 69 | 11 | 22 | 14 | 24 | 2 | 23 | 14 | 9 | 10 | 375
Study Design | Qualitative | 6 | 3 | 0 | 2 | 0 | 5 | 0 | 1 | 3 | 1 | 1 | 22
Sample Size | n < 100 | 28 | 7 | 2 | 3 | 1 | 10 | 1 | 2 | 3 | 1 | 1 | 59
Sample Size | n = 100-1,000 | 81 | 13 | 3 | 6 | 5 | 8 | 0 | 4 | 6 | 5 | 0 | 131
Sample Size | n > 1,000 | 98 | 58 | 8 | 15 | 12 | 13 | 2 | 18 | 9 | 6 | 10 | 249
Sample Size | N/A | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1
Percent Women | ≤10% | 33 | 29 | 1 | 0 | 6 | 6 | 1 | 2 | 1 | 6 | 1 | 86
Percent Women | 11-50% | 61 | 26 | 1 | 2 | 4 | 2 | 0 | 8 | 10 | 3 | 2 | 119
Percent Women | 51-99% | 14 | 6 | 1 | 1 | 1 | 1 | 0 | 3 | 3 | 0 | 2 | 32
Percent Women | 100% | 99 | 16 | 10 | 19 | 6 | 12 | 2 | 10 | 4 | 3 | 6 | 187
Percent Women | N/A (k = 13) or Not reported (k = 3) | 1 | 1 | 0 | 2 | 1 | 10 | 0 | 1 | 0 | 0 | 0 | 16
Reported race in women Veterans | | 134 | 45 | 10 | 20 | 10 | 14 | 1 | 13 | 11 | 11 | 9 | 278
Reported age in women Veterans | | 147 | 49 | 12 | 22 | 11 | 14 | 2 | 15 | 11 | 11 | 9 | 303
Special Populations | Incarcerated | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1
Special Populations | LGBT | 7 | 1 | 0 | 0 | 0 | 2 | 0 | 3 | 0 | 0 | 1 | 14
Special Populations | Racial/ethnic minorities | 5 | 1 | 0 | 1 | 1 | 2 | 0 | 2 | 0 | 0 | 0 | 12
Special Populations | Homeless | 5 | 0 | 0 | 0 | 0 | 1 | 0 | 1 | 0 | 12 | 1 | 19
Special Populations | Non-VA users | 3 | 0 | 1 | 1 | 1 | 3 | 0 | 3 | 0 | 0 | 1 | 13
Special Populations | Physically disabled | 1 | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 1 | 5
Special Populations | None | 186 | 74 | 12 | 22 | 16 | 23 | 3 | 15 | 17 | 0 | 8 | 376
Research Setting | Single site VA | 46 | 12 | 1 | 0 | 1 | 5 | 0 | 1 | 3 | 1 | 0 | 70
Research Setting | Multi-site VA | 51 | 10 | 1 | 9 | 3 | 13 | 1 | 2 | 2 | 2 | 1 | 95
Research Setting | Administrative database VA | 68 | 48 | 9 | 10 | 9 | 6 | 2 | 9 | 6 | 7 | 5 | 179
Research Setting | Non-VA healthcare setting | 0 | 1 | 1 | 0 | 0 | 1 | 0 | 2 | 0 | 0 | 0 | 5
Research Setting | Non-healthcare based | 36 | 5 | 1 | 3 | 3 | 4 | 0 | 9 | 7 | 0 | 4 | 72
Research Setting | Multiple | 7 | 2 | 0 | 2 | 2 | 2 | 0 | 1 | 0 | 2 | 1 | 19
Period of Service | OEF/OIF/OND/Persian Gulf | 45 | 15 | 0 | 7 | 1 | 1 | 0 | 9 | 13 | 3 | 1 | 95
Period of Service | Vietnam | 10 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 1 | 12
Period of Service | WWII | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Period of Service | Not specified | 153 | 63 | 13 | 17 | 17 | 30 | 3 | 15 | 4 | 9 | 9 | 333
Population | Patients | 207 | 78 | 13 | 22 | 17 | 22 | 3 | 24 | 18 | 12 | 11 | 427
Population | Clinics | 7 | 2 | 1 | 1 | 1 | 7 | 0 | 0 | 0 | 0 | 0 | 19
Population | Providers | 2 | 0 | 1 | 2 | 1 | 9 | 0 | 0 | 1 | 0 | 1 | 17
Population | Policy | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Population | Other | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1
Outcomes | Clinical | 199 | 77 | 13 | 20 | 11 | 17 | 2 | 12 | 15 | 11 | 9 | 386
Outcomes | Resource utilization | 51 | 25 | 3 | 14 | 9 | 14 | 3 | 23 | 7 | 4 | 6 | 159
Outcomes | Cost | 1 | 3 | 0 | 0 | 1 | 0 | 0 | 3 | 1 | 0 | 2 | 11
Outcomes | Other | 11 | 0 | 2 | 3 | 3 | 12 | 1 | 1 | 0 | 0 | 1 | 34
Funding source | VA | 145 | 51 | 9 | 20 | 10 | 25 | 2 | 19 | 9 | 6 | 6 | 302
Funding source | DOD | 19 | 4 | 0 | 1 | 0 | 1 | 0 | 1 | 3 | 0 | 0 | 29
Funding source | Other government (eg, NIH) | 25 | 16 | 5 | 2 | 6 | 1 | 0 | 3 | 1 | 3 | 3 | 65
Funding source | Foundation | 6 | 9 | 2 | 0 | 3 | 1 | 0 | 1 | 1 | 1 | 0 | 24
Funding source | Industry | 2 | 1 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 4
Funding source | University | 4 | 8 | 1 | 2 | 0 | 1 | 0 | 1 | 0 | 0 | 1 | 18
Funding source | Not reported | 47 | 14 | 2 | 1 | 3 | 5 | 1 | 3 | 7 | 5 | 2 | 90
Funding source | Unfunded | 3 | 2 | 0 | 0 | 1 | 0 | 0 | 1 | 0 | 0 | 0 | 7

Table 2 Overview of Mental Health Studies

| | Mental Health | | | | | | | | | | | | | | Total
| | PTSD and Trauma | MST | Substance Abuse | Depression | IPV | Personality Disorders | Anxiety | Suicide | Disordered Eating | Reproductive | Serious illness | Multiple Diagnoses | Other | Comorbid with Non-MH | Total
Study Design | RCT/CCT | 3 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 4
Study Design | Secondary or sub-group analysis of RCT/CCT | 6 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 8
Study Design | Observational (prospective cohort) | 4 | 7 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 2 | 13
Study Design | Observational (other) | 57 | 27 | 20 | 3 | 7 | 0 | 1 | 12 | 5 | 4 | 3 | 15 | 3 | 21 | 178
Study Design | Qualitative | 1 | 1 | 0 | 0 | 2 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 5
Sample Size | n < 100 | 9 | 7 | 1 | 0 | 3 | 0 | 0 | 1 | 0 | 1 | 0 | 3 | 1 | 2 | 28
Sample Size | n = 100-1,000 | 34 | 16 | 4 | 0 | 6 | 0 | 0 | 1 | 3 | 0 | 0 | 7 | 0 | 10 | 81
Sample Size | n > 1,000 | 28 | 14 | 14 | 3 | 0 | 0 | 1 | 11 | 2 | 3 | 3 | 6 | 2 | 11 | 98
Sample Size | N/A | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1
Percent Women | < / = 10% | 7 | 4 | 6 | 1 | 0 | 0 | 1 | 6 | 0 | 0 | 1 | 2 | 2 | 3 | 33
Percent Women | 11-50% | 24 | 8 | 6 | 2 | 0 | 0 | 0 | 6 | 3 | 0 | 2 | 5 | 1 | 4 | 61
Percent Women | 51-99% | 4 | 7 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 2 | 14
Percent Women | 100% | 36 | 18 | 6 | 0 | 9 | 0 | 0 | 1 | 2 | 4 | 0 | 9 | 0 | 14 | 99
Percent Women | N/A or Not reported | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1
Reported race in women Veterans | | 46 | 26 | 13 | 1 | 9 | 0 | 0 | 5 | 2 | 3 | 1 | 10 | 1 | 17 | 134
Reported age in women Veterans | | 51 | 25 | 15 | 1 | 9 | 0 | 0 | 8 | 2 | 4 | 1 | 12 | 2 | 18 | 147
Special Populations | Incarcerated | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 1
Special Populations | LGBT | 0 | 1 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 4 | 1 | 0 | 7
Special Populations | Racial/ethnic minorities | 2 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 1 | 5
Special Populations | Homeless | 1 | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 5
Special Populations | Non-VA users | 1 | 0 | 1 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 3
Special Populations | Physically disabled | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 1
Special Populations | None | 67 | 33 | 17 | 3 | 8 | 0 | 1 | 13 | 4 | 4 | 3 | 9 | 2 | 22 | 186
Research Setting | Single site VA | 18 | 12 | 3 | 0 | 3 | 0 | 0 | 0 | 1 | 1 | 0 | 3 | 1 | 4 | 46
Research Setting | Multi-site VA | 19 | 8 | 6 | 0 | 4 | 0 | 0 | 1 | 3 | 0 | 0 | 6 | 1 | 3 | 51
Research Setting | Administrative database VA | 17 | 10 | 7 | 3 | 1 | 0 | 1 | 9 | 0 | 3 | 2 | 4 | 0 | 11 | 68
Research Setting | Non-VA healthcare setting | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Research Setting | Non-healthcare based | 17 | 7 | 2 | 0 | 1 | 0 | 0 | 1 | 1 | 0 | 1 | 2 | 1 | 3 | 36
Research Setting | Multiple | 0 | 0 | 2 | 0 | 0 | 0 | 0 | 2 | 0 | 0 | 0 | 1 | 0 | 2 | 7
Period of Service | OEF/OIF/OND | 18 | 7 | 3 | 1 | 0 | 0 | 0 | 3 | 0 | 2 | 0 | 6 | 0 | 5 | 45
Period of Service | Vietnam | 9 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 10
Period of Service | WWII | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Period of Service | Not specified | 44 | 30 | 17 | 2 | 9 | 0 | 1 | 10 | 5 | 2 | 3 | 10 | 2 | 18 | 153
Population | Patients | 71 | 37 | 19 | 3 | 9 | 0 | 1 | 13 | 5 | 4 | 3 | 16 | 3 | 23 | 207
Population | Clinics | 1 | 1 | 3 | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 7
Population | Providers | 0 | 1 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 2
Population | Policy | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Population | Other | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Outcomes | Clinical | 68 | 35 | 17 | 3 | 9 | 0 | 1 | 13 | 5 | 4 | 2 | 16 | 3 | 23 | 199
Outcomes | Resource utilization | 16 | 11 | 4 | 3 | 1 | 0 | 1 | 0 | 0 | 0 | 2 | 5 | 0 | 8 | 51
Outcomes | Cost | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 1
Outcomes | Other | 5 | 0 | 4 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 1 | 11
Funding source | VA | 49 | 25 | 19 | 2 | 7 | 0 | 1 | 8 | 3 | 2 | 3 | 7 | 1 | 18 | 145
Funding source | DOD | 14 | 1 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 2 | 0 | 1 | 19
Funding source | Other government (eg, NIH) | 10 | 1 | 2 | 1 | 1 | 0 | 0 | 2 | 0 | 1 | 1 | 0 | 0 | 6 | 25
Funding source | Foundation | 1 | 0 | 1 | 0 | 0 | 0 | 0 | 2 | 0 | 1 | 0 | 1 | 0 | 0 | 6
Funding source | Industry | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 2 | 2
Funding source | University | 3 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 4
Funding source | Not reported | 17 | 11 | 1 | 1 | 2 | 0 | 0 | 1 | 2 | 1 | 0 | 5 | 2 | 4 | 47
Funding source | Unfunded | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 2 | 0 | 0 | 3

Table 3 Overview of Medical Studies

| | Medical Conditions | | | | | | | | | | | | | | Total
| | Chronic Pain | Cancer | SCI | TBI | HIV | MS | Tobacco | Obesity | Diabetes | Hypertension | CVD | Amputation | Comorbidities | Other | Total
Study Design | RCT/CCT | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Study Design | Secondary or sub-group analysis of RCT/CCT | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1
Study Design | Observational (prospective cohort) | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 3 | 1 | 0 | 0 | 0 | 0 | 0 | 5
Study Design | Observational (other) | 5 | 6 | 1 | 5 | 4 | 4 | 4 | 6 | 2 | 0 | 11 | 1 | 7 | 13 | 69
Study Design | Qualitative | 2 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 3
Sample Size | n < 100 | 3 | 2 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 7
Sample Size | n = 100-1,000 | 1 | 1 | 0 | 1 | 0 | 0 | 2 | 2 | 0 | 0 | 2 | 0 | 1 | 3 | 13
Sample Size | n > 1,000 | 3 | 3 | 1 | 4 | 5 | 4 | 3 | 7 | 3 | 0 | 9 | 1 | 6 | 9 | 58
Sample Size | N/A | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Percent Women | < / = 10% | 1 | 0 | 1 | 3 | 4 | 1 | 4 | 2 | 2 | 0 | 5 | 1 | 2 | 3 | 29
Percent Women | 11-50% | 3 | 1 | 0 | 0 | 1 | 3 | 0 | 6 | 1 | 0 | 2 | 0 | 3 | 6 | 26
Percent Women | 51-99% | 2 | 1 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 2 | 6
Percent Women | 100% | 1 | 4 | 0 | 1 | 0 | 0 | 2 | 0 | 0 | 0 | 4 | 0 | 2 | 2 | 16
Percent Women | N/A or Not reported | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1
Reported race in women Veterans | | 5 | 5 | 1 | 3 | 2 | 1 | 0 | 4 | 1 | 0 | 10 | 0 | 4 | 9 | 45
Reported age in women Veterans | | 6 | 6 | 1 | 4 | 2 | 0 | 1 | 4 | 2 | 0 | 9 | 1 | 4 | 9 | 49
Special Populations | Incarcerated | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Special Populations | LGBT | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1
Special Populations | Racial/ethnic minorities | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 1
Special Populations | Homeless | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Special Populations | Non-VA users | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Special Populations | Physically disabled | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 2
Special Populations | None | 7 | 5 | 0 | 5 | 5 | 4 | 6 | 9 | 3 | 0 | 10 | 0 | 7 | 13 | 74
Research Setting | Single site VA | 3 | 0 | 0 | 0 | 1 | 0 | 2 | 0 | 0 | 0 | 2 | 0 | 0 | 4 | 12
Research Setting | Multi-site VA | 0 | 0 | 0 | 3 | 1 | 0 | 1 | 0 | 0 | 0 | 3 | 0 | 0 | 2 | 10
Research Setting | Administrative database VA | 3 | 5 | 1 | 2 | 3 | 4 | 1 | 9 | 3 | 0 | 5 | 1 | 7 | 4 | 48
Research Setting | Non-VA healthcare setting | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 1
Research Setting | Non-healthcare based | 1 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 1 | 0 | 0 | 2 | 5
Research Setting | Multiple | 0 | 1 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 2
Period of | OEF/OIF/OND/Persian Gulf | 2 | 0 | 0 | 2 | 0 | 2 | 0 | 2 | 0 | 0 | 0 | 1 | 3 | 3 | 15
Period of | Vietnam | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Period of | WWII | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Period of | Not specified | 5 | 6 | 1 | 3 | 5 | 2 | 6 | 7 | 3 | 0 | 11 | 0 | 4 | 10 | 63
Population | Patients | 7 | 6 | 1 | 5 | 5 | 4 | 6 | 9 | 3 | 0 | 11 | 1 | 7 | 13 | 78
Population | Clinics | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 1 | 0 | 0 | 0 | 2
Population | Providers | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Population | Policy | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Population | Other | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1
Outcomes | Clinical | 7 | 6 | 1 | 4 | 5 | 4 | 6 | 9 | 3 | 0 | 11 | 1 | 7 | 13 | 77
Outcomes | Resource utilization | 2 | 4 | 1 | 2 | 1 | 0 | 0 | 1 | 2 | 0 | 4 | 0 | 3 | 5 | 25
Outcomes | Cost | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 1 | 0 | 0 | 1 | 3
Outcomes | Other | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Funding source | VA | 5 | 2 | 1 | 5 | 3 | 4 | 3 | 7 | 3 | 0 | 6 | 0 | 6 | 6 | 51
Funding source | DOD | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 2 | 0 | 0 | 0 | 0 | 0 | 2 | 4
Funding source | Other government. (eg, NIH) | 2 | 1 | 0 | 0 | 2 | 0 | 1 | 0 | 2 | 0 | 3 | 0 | 3 | 2 | 16
Funding source | Foundation | 0 | 0 | 0 | 0 | 1 | 3 | 2 | 0 | 0 | 0 | 1 | 0 | 0 | 2 | 9
Funding source | Industry | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 1
Funding source | University | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 1 | 0 | 1 | 0 | 2 | 1 | 8
Funding source | Not reported | 0 | 2 | 0 | 0 | 2 | 0 | 2 | 1 | 0 | 0 | 3 | 1 | 0 | 3 | 14
Funding source | Unfunded | 1 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 2

Figure 1 Mental Health Studies by Sub-category, Sample Size, Study Design, and Proportion of Women

[image] Dark Blue = RCT/CCT; [image] Light Blue = Secondary Analysis of RCT/CCT; [image] Red = Observational Study; [image] Green = Qualitative Study

● 100% women; ○ < 100% women

a One additional observational study of facilities; size of study and % women not applicable

Figure 2 Medical Condition Studies by Sub-category, Sample Size, Study Design, and Proportion of Women

[image] Dark Blue = RCT/CCT; [image] Light Blue = Secondary Analysis of RCT/CCT; [image] Red = Observational Study; [image] Green = Qualitative Study

● 100% women; ○ < 100% women

a One additional observational study with n > 1,000, % women not reported