# APPENDIX A SEARCH STRATEGIES

## OVID MEDLINE and CINAHL

Search Terms | Description
1 Women/ | MeSH Term
2 Women's Health/ | MeSH Term
3 Women's Health Services/ | MeSH Term
4 Transgendered Persons/ | MeSH Term
5 (reproductive or reproduction or pregnan* or birth* or fertility or infertility or infertile or menstrual or menstruation or menses or urinary tract or sexually transmitted or hiv or cervical or ovarian or genital or gynecologic* or breast or congenital abnormalities).mp. | Search with .mp (see footnote) for any of the listed words related to women's health issues
6 1 or 2 or 3 or 4 or 5 | Combine with “or” lines 1-5 above; carry forward all articles identified with one of the terms in lines 1-5
7 Veterans/ or Veterans Health/ or “United States Department of Veterans Affairs”/ | MeSH term
8 (post deployment or post-deployment).mp. | Search with .mp for post-deployment
9 (VA or VHA or VAMC or veteran*).mp. | Search with .mp for Veteran health abbreviations or Veteran/Veterans
10 Hospitals, veterans/ | MeSH term
11 7 or 8 or 9 or 10 | Combine with “or” lines 7-10 above; carry forward all articles identified with one of the terms in lines 7-10
12 6 and 11 | Combine with “and” lines 6 and 11; carry forward all articles from women's health terms and Veteran terms
13 ((women or LGBT or gay or lesbian or bisexual or female or transgender or transsexual or queer) and veteran*).ti,ab. | Search title and abstract for veteran “and” any of the terms in parentheses (“or”) l
14 12 or 13 | Combine with “or” lines 12-13; carry forward all articles from overall search and focused search in line 13
15 Limit 14 to (English language and yr = ”2008-Current”) | Include only studies published in English and published from 2008 to the date of the search

.mp = multi-purpose (OVID); fields searched by a .mp search include Title, Original Title, Abstract, Subject Heading, Name of Substance, and Registry Word fields MeSH = Medical Subject Heading (MEDLINE)