# RESULTS

## LITERATURE FLOW

Our search identified 675 titles of potential relevance. Of these titles, 118 were duplicate references to a study, 151 were rejected as not being relevant to the topic, and 26 could not be retrieved. Of the remaining 380 articles that were evaluated as full-text articles by at least two physician reviewers independently, 154 were rejected because they did not meet our inclusion criteria; 48 did not relate to U.S. veterans or military personnel; and 106 failed to meet at least one of the following additional criteria. Thirty-one articles were excluded because the study design was not appropriate: 4 articles were non-systematic reviews, 22 were editorials or commentaries, and 5 articles had unclear design.

Further data abstraction was performed on the remaining 195 articles, and all were categorized into the following 5 areas, which were not mutually exclusive: deployment and post-deployment health issues (n=33); organizational research (n=7); quality of care (n=54); access and utilization (n=48); and psychiatric conditions (n=85) (See Figure 2).

Figure 2 Literature Flow

## DESCRIPTION OF EVIDENCE

As in the baseline systematic review1, the majority of articles discussed observational or descriptive studies. Nearly half of the research articles focused on psychiatric issues (e.g., screening for mental health conditions or for post traumatic stress disorder (PTSD).

Only five studies were identified as experimental studies or clinical trials. Of these, three focused on women veterans or military personnel with PTSD diagnosis or symptoms5–7, one on VA employees’ perceptions about women veterans8 and one on improving mammography screening among women veterans9. Compared to the initial systematic review, these trials highlight a few key advances in methods by including the first VA multi-site randomized controlled trial on women veterans using the cooperative study program, and a moderately large sized mental health patient sample (N=284)6.

Due to the broad scope of research contained in this report, each study has to be interpreted subject to its own limitations, and it is not feasible to include all the caveats and constraints within this document. Before citing specific findings, the reader should refer to the source article to understand the context of the research methods and findings.

### DEPLOYMENT AND POST-DEPLOYMENT HEALTH

Thirty-three articles covered deployment and post deployment-health issues, with the majority of studies (n=23) addressing health issues specific to OEF/OIF veterans10–32. The OEF/OIF topics focused on mental health screenings, general women’s deployment health issues, validation of the deployment risk and resilience inventory (DRRI), and psychiatric diagnoses associated with medical evacuation from the combat theatre. The remaining articles consisted of deployment studies in non-OEF/OIF cohorts (n=10)33–42.

#### Studies Specific to OEF/OIF

Twenty-three studies addressed post-deployment health issues specific to OEF/OIF veterans; most focused on general mental health screening/utilization, PTSD symptoms, or access to services while deployed or upon return post-deployment.

##### Mental Health Screening and Utilization

The bulk of articles focused on mental health issues and OEF/OIF deployment. In this group (n=14), the majority of studies focused on mental health screening before, during, or after deployment among military personnel or recently returning veterans10–13, 15, 17, 20–25, 27, 28. Four themes are prominent in these studies: (1) high rates of screen positive PTSD symptoms (range 10–19%)10, 11, 13, 15, 23, 28 or other mental health disorders11, 12, 15, 17, 20–22, 24, 28 occur among OEF/OIF returning military women; (2) women in the military who recently returned from OEF/OIF deployments are disproportionately or more affected by symptoms of PTSD, symptoms of depression, other mental health issues or more likely referred for mental health care compared with men in the military who were recently deployed11, 20, 22, 28; (3) younger age and separated or divorced marital status tend to place military members at risk for more mental health symptoms21, 22, 25; and (4) a greater number of OIF deployments appears to be associated with screening positive for mental health problems17, 20, 22.

##### PTSD Symptoms in OEF/OIF

Two studies assessed general assault history or Military Sexual Trauma (MST) history10, 16. The first by Smith and associates identified a doubled rate of new onset PTSD symptoms among combat military women (22% vs 10%) who had been exposed to assault prior to combat vs not, and also among military men (12% vs 6%)10. The second by Katz et al evaluated a small group of women (n=18) previously deployed who were referred for mental health care and compared their readjustments to civilian life and experiences in war compared with men. Over half the group (56%) were identified as having a MST history, based on a 3-item screen16. The two major study findings were that (1) of three types of events (MST, being injured, and witnessing others injured or killed), only MST was significantly related to the severity of clinical symptoms and difficulty with readjustment to civilian life, and (2) women who had MST had more symptoms and more difficulties with readjustment to civilian life than those without MST.

##### Access to Services

A salient finding by Seal and associates related to managing mental health symptoms and diagnoses was that mental health visits occurring within 90 days of screening were more likely to occur in veterans seen in VA community clinics versus the medical center (aOR 6.08; 95%CI 1.56, 23.6) or seen in any VA primary care clinic compared with other VA outpatient settings (aOR 19.4; 95%CI 1.30, 290)24. One small study captured potential barriers to mental health treatment reported by OIF National Guard soldiers, including stigma associated with seeking mental health treatment, pride, not being able to ask for help, and not being able to admit to having a problem27.

Two additional studies analyzed the psychiatric diagnoses associated with medical evacuation from the theatre of combat18, 19. Stetz et al. analyzed the characteristics and diagnoses of medical evacuees from combat theatres during 2001–2003^18^. Women represented 16 and 18% of OIF and OEF evacuees respectively, and psychiatric diagnoses were the 2^nd^ most common reason for evacuation from OEF and the 4^th^ most common reason in OIF for the group overall. Rundell et al. found that psychiatric evacuees were more likely to be women, African-American or Hispanic, under the age of 31, and enlisted in the National Guard Reserve, as opposed to active duty military19. The most compelling finding was that women were overrepresented as psychiatric evacuees by a factor of 2.

A single study by Pierce on pregnant women32 with recently deployed partners showed that these women often reported higher stress levels than those with homeland partners (39.6% and 24.2%; p<0.01). Regression analyses revealed that having a partner deployed, being active duty, advanced gestational age, and having >1 child at home (OR 2.30, 95% CI 1.12–4.73) all predicted higher stress reporting. However, having a support person present was protective against stress (OR 0.40, 95% CI 0.20–0.78). These data included both military and nonmilitary pregnant women living on base and obtaining obstetric care at Naval Hospital.

##### General Deployment Health Issues

Two studies focused on military women in the field of duty29, 30. The Farley and colleagues document the number of gynecologic visits to a far forward combat support hospital at Bagram Air Force Base in Afghanistan compared with transport out of the regional area to Germany and the average number of work hours lost29. Over 90% of women (57 of 62) were seen in theatre at the Air Force Combat Support Hospital (CSH). Most patients had abnormal cervical cytology and colposcopies; other diagnoses included pregnancy, dysfunctional uterine bleeding and pelvic pain. The average work time loss during in theatre treatment was 6 woman-hours per patient compared with 216 hours per patient with travel to Germany. This paper underscores the benefits of providing far forward gynecology care (or gender-specific care) in the theatre of operations in order to maintain military readiness.

The second study by Thomson and colleagues anonymously surveyed women in the military deployed to Iraq or Kuwait for at least 3 months to assess their perceptions of health care delivery in OIF at the front line and aid stations30. Irregular bleeding (26%) and changes in hormonal contraception (23%) were the most common complaints among soldiers. Additionally, 21% of soldiers experienced some type of gynecological problem, and nearly one-half of patients (44%) did not meet the cervical cytology screening practice guidelines.

These studies highlighted the need to (1) complete routine gynecological screening at least 6 months before deployment to account for any abnormal results and allow for follow up, (2) educate non-gynecologic medical personnel on gender-specific issues, especially related to cycle control and contraception, and (3) provide at least a 3 month and preferably 6–12 month supply of hormonal contraception for women deployed. Each of these issues affects the military readiness of women soldiers.

##### Deployment Risk and Resilience Inventory

A single study by Vogt and associates validated 9 scales of the Deployment Risk and Resilience Inventory (DRRI) among a sample of OIF active duty soldiers who participated both before and after deployment31. In general, all DRRI scales demonstrated reasonable to excellent values for internal consistency and reliability (coefficient alpha or cronbach’s alpha ranged from 0.77 to 0.90) suggesting that the item sets converged on a common construct. Only one construct had a lower cronbach’s alpha (alpha = 0.55), and it was related to post deployment life stressors. Significant gender differences emerged for 5 of the DRRI scales. Men reported greater exposure to combat and aftermath of battle and more often reported being well prepared for deployment, and women reported greater perceived threat and less preparedness for battle compared with the men.

##### Other Studies

The remaining studies covered a sundry of topics ranging from environmental and physical health exposures reported by veterans (e.g., burning of trash and feces in OIF, genitourinary concerns)14, to case reports on the use of aripiprazole with sertraline or cognitive behavioral therapy for the treatment of PTSD symptoms such as sleep disorders in returning combat veterans26.

#### General Deployment Issues - Non OEF/OIF

OEF/OIF deployment and mental health findings are described above in Studies Specific to OEF/OIF. The remaining ten deployment and mental health articles are not specific to the OEF/OIF cohorts33–42. A study on Bosnian peacekeeping veterans showed that longer deployments and first time deployments were associated with increased distress scores for male soldiers specifically; longer deployments did not show this effect in women veterans33. Among a sample of Vietnam veteran females, those who had a history of PTSD symptoms were susceptible to greater distress after the onset of Operation Desert Storm across all PTSD symptoms of re-experiencing, avoidance/numbing, and hyperarousal37. In contrast, risk of a mental health related hospitalization was lower among women in combat support occupations compared to women in non-combat support (HR0.64, 95% CI 0.53, 0.77) in a study occurring prior to the onset of OEF/OIF35. Among a mixed gender group of Gulf War I veterans, lower levels of social support resulted in increased depression symptoms for women, and increased levels of sexual harassment resulted in increased depression symptoms for men but not women suggesting that social support was a greater risk factor for depression in women and sexual harassment was a stronger risk factor for men34. Even in a small mixed gender case series of World War II veterans, 25% still had some PTSD symptoms 50 years after war36. The authors of this study suggest that studies of high functioning female and male veterans who have survived combat experiences and other trauma may be needed to provide more insight to veteran experiences and resiliency.

The baseline health status (physical and mental health component scores) of a large population-based military cohort is slightly more favorable than that of the same-age, same-sex U.S. general population, especially among older age groups, and also much higher than levels reported in VA populations presenting for care38. Deployment experiences were not associated with either decreased overall health status or mental well being38, 39. However, after adjustments for socio-demographics, deployment experience in SW Asia, Bosnia, or Kosovo (from 1998–2000), and deployment to the 1991 Gulf War, active-duty women health care specialists were significantly more likely to report witnessing death or trauma when compared to combat specialists40. In addition, Air Force women deployed to theatre during the Gulf War reported significantly more general as well as gender-specific health problems than did women deployed elsewhere39. Common health problems included: skin rash; cough; depression; unintentional weight loss; insomnia; and memory problems and a significant increase in gender-specific problems compared to women deployed elsewhere (e.g., abnormal pap, breast problems).

Two additional studies covered deployment related reproductive and pregnancy issues41, 42. The most prevalent gender-specific problems among an active duty sample (from Persian Gulf War) were problems during pregnancy (41%), urinary tract infection (34%), headache (33%), menstrual irregularities (32%) and abnormal Pap smear (27%)42. In this group, 76% reported using military health care, 41% used civilian health care, and only 3% reported using the VA. Overall, satisfaction ratings were higher for civilian care, and too few patients attended the VA to provide satisfaction ratings.

Another study41 compared conceptions and pregnancy loss among Gulf War exposed conceptions and non-deployed conceptions among veterans and found similar outcomes. Separately, GW veteran postwar conceptions were at increased risk for ectopic pregnancies and spontaneous abortions, but the study was limited due to lack of information on risk factors for and documentation of fetal loss.

#### Summary

The large number of studies focused on the health issues of OEF/OIF soldiers reflects the growing participation of women in these conflicts. More than half of the OEF/OIF articles underscore the need to screen for PTSD and other mental health symptoms among recently returning soldiers who might have multiple risk factors. A key finding is that psychiatric diagnoses were common for both OEF and OIF evacuations, suggesting the need for DOD and VA to ensure that military personnel evacuated from the field for mental health issues receive ongoing care.

Two other salient issues arose in this section. First, both women and men with assault histories prior to combat had double the rates of new onset PTSD symptoms. Second, military readiness for women includes field access to gynecological services. These issues will be key for both DOD and VA in post-deployment health care settings.

### ORGANIZATIONAL RESEARCH

The seven studies in this category all examined organizational characteristics of clinics delivering services to women in a national or regional sample of VA sites for primary care 43–49.

#### Services Available to Women

A national survey of VA facilities delivering primary care documented that 61% had established women’s health clinics (WHC) for primary care; the main factor significantly related to the presence of WHCs was separate primary care leadership (OR 3.62, 95% CI 1.45–9.05)43. Three papers evaluating VA sites across the country serving 400 or more women veterans defined the presence of emergency services for women and the breadth and depth of gynecological services in the VA. Washington and colleagues assessed whether women’s health care specialists for emergency gynecological problems or for emergency mental health conditions were available during and after clinic hours46. They found that while most sites had a specialist available for gynecologic and mental health emergencies during clinic hours, rates dropped for after-hour emergencies. Predictors of specialist availability were presence of a separate WHC for gynecological emergencies and lower local managed care penetration for mental health emergencies.

Cope and colleagues evaluated the availability of different forms of contraception in VA47. While 97% of VA sites provided hormonal contraception, only 60% of offered intrauterine devices (IUDs). Factors related to IUD service availability were hospital-based facility (in contrast to community-based outpatient clinic), on site gynecologist, and availability of a women’s health clinician who trained other clinicians. Seelig and colleagues built on this work by assessing availability of gynecologic services across VA44. They found that availability of endometrial biopsy, IUD, infertility evaluation, infertility treatment, and general gynecologic surgery were directly related to routine availability of an Ob/Gyn physician.

#### Practice Environment

Hall et al. presented an assessment of organizational factors impacting the MST practice environment and perceived organizational support using key surveys of MST health providers in a VA geographical region48. Wide variability in the perception of organizational support existed among facilities even with a small sample size. Ethical conflicts, burnout, vicarious trauma experiences (i.e., from counseling), and isolation had negative correlations with perceived organizational support while workload, organizational culture, leadership, and MST resources were positively correlated with perceived organizational support.

Two studies focused on the organizational features associated with the adoption of women’s health centers into VA sites43, 49. The first43 examined primary care organizational features influencing the development of women’s clinics in primary care (VAMCs or CBOCs) and found that nearly two-thirds of VAMCs had women’s clinics (64%), but the only factor significantly associated with their presence was separate strong primary care leadership (OR 3.62, 95% CI 1.45, 9.05). Separately, Yano and colleagues49 identified the degree to which VA medical centers had adopted women’s clinics as an organizational innovation by comparing their structure and services to the 8 original Comprehensive Women’s Health Centers (CWHCs) in VA. Gender specific service availability was comparable to the CWHCs with the exception of onsite mammography, osteoporosis assessment, and availability of separate mental health clinics49. While the general WHCs were less likely to have same gender providers, women’s health training programs, separate space, or adequate privacy, they also were less likely to experience educational program closures or staffing losses.

The final study compared the original 8 VA Comprehensive Women’s Health Centers with the Department of Health and Human Services (DHHS) National Centers of Excellence in Women’s Health45. These prototype women’s health centers had many parallel organizational characteristics (e.g., training or fellowship programs, quality monitoring activities, and extended hours or same gender providers) and uniformally provided preventive cancer screening, and general reproductive services. However, DHHS sites had more extensive reproductive care on site, and VA centers had more on-site mental health care.

#### Summary

Two issues are salient in this area. Presence of an Ob/Gyn physician in the VA or a separate gynecology or women’s clinic in the VA improves the availability of IUD contraception, advanced gynecologic services, and emergency gynecologic services after hours. Separately, organizational culture and leadership showed positive associations with the practice environment for MST providers and with sites reporting separate women’s clinics delivering primary care, indicating that key role of VA local leadership in women veteran care.

### QUALITY OF CARE

Our summary of the quality of care literature on women veterans included fifty one studies that covered the following areas: patient perceptions of quality and ratings of satisfaction50–58, general quality of care processes and outcomes59–68, surgical outcomes69–72, prescription medication issues73–77, cardiovascular risk factors and health disparities59, 60, 62, 63, 69, 70, 78–80, gender-specific and reproductive care32, 41, 42, 81–91, other quality of care issues92–98, and two clinical trials8, 9.

#### Patient Perceptions of Quality and Satisfaction

Patient preferences in VA care among women veteran users and non-users were explored through a qualitative study by Washington and colleagues, which demonstrated knowledge gaps about VA eligibility and services51. These gaps included a general lack of information about VA eligibility and available services; nonusers often assumed that the VA did not provide women’s health care. Separately, both users and nonusers identified the availability and accessibility of physicians and treatments, gender specific knowledge and sensitivity, and quality expertise and knowledge among the physicians/providers as expectations for their care. However, users and nonusers differed in perceptions of VA quality, and VA environment and quality concerns led many women to limit their VA use to women’s clinics.

In a regional study of women veterans, Bean-Mayberry and associates examined patient race and primary care ratings in VA50. Race had no association with any of four primary care domains or with overall satisfaction with VA care. Separately, patients who reported that they received routine gynecological care from VA providers gave high ratings on preference for provider (OR 2.0, 95% CI 1.3, 3.1) and satisfaction (OR 1.6, 95% CI 1.2, 2.3).

##### Women’s Clinics Versus Traditional Clinics

In a comparison of women veterans using women’s clinics versus traditional primary care clinics, Bean-Mayberry et al. found that female veterans who were seen in the women’s clinics were more likely to report excellent satisfaction compared with those seen in traditional clinics (p<.05, OR 1.42, 95% CI 1.00, 2.02)52. Similarly, for every domain in the original version of the Primary Care Satisfaction Survey for Women, patients seen in women’s clinics were significantly more likely to report the highest satisfaction rating: getting care (OR 1.69, 95% CI 1.14, 2.49); privacy and comfort (OR 1.63, 95% CI 1.11, 2.39); communication (OR 1.66, 95% CI 1.16, 2.37); complete care (OR 1.69, 95% CI 1.17, 2.43); and follow up care (OR 1.70, 95% CI 1.16, 2.47).

##### Inpatient/Outpatient Satisfaction

Wright and associates compared patient satisfaction among male and female veterans in inpatient and outpatient settings in the VA nationally53. They found that in adjusted analyses, overall quality perceptions and most dimensions of satisfaction with outpatient care were not different for females compared with males. However, women were less satisfied than men for inpatient settings in multiple domains. Men reported higher scores for inpatient quality, after adjustment for transitions (68 vs. 65, p=0.0009), physical comfort (82 vs. 80, p=0.0003), involvement of family and friends (74 vs. 71, p=0.0024), courtesy (88 vs. 86, p=0.0001), coordination (77 vs. 74, p=0.0000), and access (80 vs. 76, p=0.0000).

##### Gender and Gynecological Services

Bean-Mayberry and colleagues determined whether the separate or combined effects of provider gender, gynecologic services from the provider, and women’s clinic setting improved patient ratings of primary care54. Each combination was compared to a baseline of male provider, no gynecologic care from provider and no women’s clinic setting. Having a female provider was significantly associated with the highest ratings for communication (OR 2.9, 95% CI 1.4, 5.8) and coordination (OR 3.7, 95% CI 1.5, 9.0). Male providers who provided gynecologic care or had patients enrolled in women’s clinic had a higher rating of coordination (OR 3.0, 95% CI 1.2, 7.0) (compared with male providers who did not). Female providers who performed gynecological services also had significant positive associations in 3 of 4 domains: continuity (OR 4.0, 95% CI 1.8, 8.7); communication (OR 2.7, 95% CI 1.3, 5.5); and coordination (OR 2.8, 95% CI 1.1, 7.1). Similar findings occurred for patients who had all 3 factors (female provider, received gynecologic services, and used a women’s clinic setting).

Fan and associates evaluated the relationship between continuity of care and satisfaction among women and men veterans in primary care at 7 medical centers using the Seattle-based Outpatient Satisfaction Questionnaire which has both a humanistic and organizational scale57. The humanistic scale measures satisfaction with communication skills and humanistic qualities of the providers, and the organizational scale measures satisfaction with the delivery of health care services. Higher patient reports of continuity of care were associated with higher patient satisfaction. Patients who reported always seeing the same provider had higher mean humanistic scores and mean satisfaction scores than those who rarely or never saw the same provider. Additionally, female patient gender and increasing age was associated with improved satisfaction and higher humanistic scores.

##### Mental Health

Two studies assessed the association of mental health with satisfaction in primary care55, 58. The first surveyed women in one VA healthcare system to identify the associations between satisfaction in general medical clinics and trauma-related mental health symptoms. The study found that women with more PTSD symptoms appeared to be more satisfied with their overall care and with their provider55. Separately, Desai and colleagues, evaluating VA patients with and without psychiatric illnesses who responded to a national VA satisfaction survey, found that patients with mental health diagnoses had lower satisfaction in outpatient primary care58. Dissatisfaction was associated with poorer perceptions of access to care and overall coordination of care.

##### Maternity Care

One study evaluated women’s satisfaction with maternity care in 44 military hospitals and found that less than 50% of the respondents would recommend their hospital of care to family or friends due to a higher-than-average rate of problems with care56. Although this study had a fairly low response rate (41%), the data identify multiple quality and satisfaction issues: problem rates were significantly higher for these women compared with average Picker scores from patients nationwide. Military women reported worse ratings on satisfaction domains or items covering confidence and trust in provider, treatment with respect and dignity, involvement with medical decision-making, and coordination of care (p<.0001 for each). These experiences are directly related to maternity care in military hospitals; however, such experiences may affect expectations about potential VA health care after active duty.

#### General Quality of Care Prevention, Processes and Outcomes

Ten quality of care studies focused on general prevention and chronic disease processes59–68.

One study, which focused on patterns of colorectal cancer screening in fiscal year 2002, noted that screening was most likely in patients aged 70–80 years. Factors associated with lower screening included: female gender; black race; lower income; infrequent primary care visits; and recent admission to a nursing home setting61. One salient clinical finding was that 41% of patients with a positive fecal occult blood test were not offered any type of colon examination within a 6-month window. Another study66 explored the barriers, attitudes and preferences for colorectal cancer (CRC) screening by gender and found that female and male participants reported similar preferences for CRC screening mode, but women viewed the preparation for endoscopic procedures as a major barrier to screening while men did not. Women also expressed different fears from men (vulnerability vs. pain) and perceived CRC as a male disease thus feeling less vulnerable to CRC. These gender-specific barriers may help explain women’s lower rate of screening for CRC. In a separate analyses examining flu vaccination by race among outpatient veterans age 50 and older (in 2003–04) in the VA, gender did not have any effect on vaccination for the 121,738 veterans surveyed67. Jha and coworkers evaluated multiple prevention and chronic disease measures in fiscal year 2000 and documented comparable overall care for both men and women overall in VA, although a few quality measures varied by age and sex62. Among those less than 65 years, women were more likely to receive hemoglobin A1c testing (OR 1.13, 95% CI 1.03–1.25) and adequate hypertension control (OR 1.09, 95% CI 1.00–1.18) but less likely to receive pneumococcal vaccine (OR 0.78, 95% CI 0.73–0.83). For patients age 65 and older, women were less likely to receive adequate hypertension control (OR 0.82, 95% CI 0.75–0.90) or pneumococcal vaccine (OR 0.92, 95% CI 0.86–0.99).

Tseng and colleagues performed 2 studies with veteran populations with diabetes. The first, which compared older male and female veterans with non-veterans enrolled in Medicare to examine gender differences in process of care measures, found no differences in glycosylated hemoglobin (HbA1c), or low density lipoprotein cholesterol (LDL-C) testing59. Women were more likely to have completed eye exams but less likely to have LDL-C under 130mg/dl compared with men.

In a separate diabetes study comparing female veterans with and without service connected disability status, women veterans with service connection were more likely to receive recommended diabetes tests compared with women veterans without service connection, but were less likely to have LDL-C controlled even though they were more likely to be tested60. The last study in this section focused on cardiovascular risks in veterans with HIV. Among HIV positive veterans started on protease inhibitors for disease control, 60% achieved the recommended lipid screening guidelines63. Notably, female gender was not a factor associated with receipt of lipid screening in either unadjusted or adjusted analyses.

The remaining three articles64, 65, 68 described tobacco use and development of a tobacco cessation program for women veterans. Vander Weg68 evaluated use of various tobacco products among the military by gender and noted use of any type of alternative tobacco products (e.g., bidics, cigars, kretekcs, pipes, and smokeless tobacco) was greater among cigarette smokers compared to non-cigarette smokers, and use of alternative products was consistently higher for males than for females. The qualitative articles described the development process for selecting ideal components of a smoking cessation program for women veterans and uncovered the finding that women veterans wanted both formal and informal support mechanisms (professional and peer support) in addition to choice for a smoking cessation program (new vs. traditional alcoholics anonymous style)64. When women in these focused groups were given a VA tailored smoking cessation booklet to choose options from, most women selected multiple options for cessation and least often chose the traditional VA program65.

#### Surgical Outcomes

Four research studies focused on surgical outcomes in women patients or diseases predominant in women (e.g., breast cancer surgery)69–72. Johnson and colleagues evaluated postoperative morbidity and mortality among women patients (n=458 VA patients and n=3535 non-VA patients) undergoing vascular surgery at multiple VA and private hospitals69. In the stepwise logistic regression models adjusted for clinical and operative characteristics, VA and private sector hospitals showed no difference in mortality; however, VA care was associated with significantly lower morbidity (OR 0.60, 95% CI 0.44–0.81).

Fink and colleagues also evaluated post-operative morbidity and mortality among female surgical patients (n=5157 VA patients and n=27,467 non-VA patients) undergoing general surgery procedures in VA and private sector hospitals71. They found that risk adjusted morbidity was significantly lower in the VA compared with the private sector (OR 0.80, 95% CI 0.71–0.90), however, risk-adjusted mortality did not differ. The next study focused on surgical morbidity and mortality outcomes for breast surgery (n=1333) performed at VA hospitals over a 6-year period (1991–1997)72. Of those diagnosed with breast cancer (n=478), 75% were women. Thirty-day morbidity rates (12%), 30-day mortality rates (1%), and 1-year operation related readmission rates (<1%) were all low for both the women and men in VA. The most common post-operative complications were wound infections for both women and men, and urinary tract infections in women. Women breast cancer patients were more likely to be younger, unmarried, and low income compared with men.

The last study focused on surgical outcomes in VA and non-VA patients of both genders undergoing gastric bypass70. This surgical study evaluated 30-day post operative morbidity outcomes and predictors of morbidity in VA and non-VA male and female patients (veterans and non-veterans) undergoing Roux-en-Y gastric bypass surgery. The adjusted odds of postoperative morbidity for the VA versus non-VA female patients was 1.14 (95% CI 0.63–2.05), and for male patients was 2.29 (95%CI 1.28–4.10). Although the VA male subset showed high risk-adjusted postoperative morbidity, both the unadjusted or adjusted findings for VA females were equivalent to those of non-veteran females.

#### Prescribing Outcomes

We reviewed five studies that focused on prescribing outcomes73–77. In a VA and Medicare comparison paper, Barnett and colleagues found that VA users had lower rates of any inappropriate medication prescribed overall (21% vs. 29%, p<0.001), and the rate of inappropriate drug use was lower in VA compared with the private sector for males (21% vs. 24%, p<0.001) and females (28% vs. 32%, p<0.001)75.

Three studies focusing only on VA populations showed that inappropriate prescribing was more likely to occur in VA women whether using Beers criteria73, HEDIS 2006 criteria74, or Zhan criteria76. In addition, gender-stratified analyses found that only geriatric care was protective against inappropriate prescribing for women. An additional study compared antidepressant treatment between the VA and private sector patients and found more than 80% of patients achieved guideline acute phase treatment (i.e., effective antidepressant medication therapy during the first 84 days after depression diagnosis) with little differences between VA and private sector77. Predictors of quality treatment included female gender, and comorbid substance abuse or other mental health diagnoses.

Pugh and colleagues identified inappropriate prescribing using multiple criteria (AHRQ, Beers, and Zhan)76. The Agency for Healthcare research and Quality (AHRQ) criteria included documentation of certain drugs by the categories of always avoid, rarely appropriate, or some indications while the Beers criteria involved the medications that should be avoided in persons aged 65 and older due to ineffectiveness or high risk to safety and medications that should not be used in older persons with specific conditions99. The AHRQ panel further identified situations in which use of rarely appropriate and some-indications drugs are proper (i.e., Zhan criteria). The study found that adjustment for clinical diagnoses decreased inappropriate prescribing practices from 33 to 23% of all veterans and showed that inappropriate drug exposure was prolonged (means not given). Multivariate analyses revealed that women were more likely than men to be prescribed inappropriate drugs using Zhan criteria (OR 1.3, 95% CI 1.2–1.3), and were less likely to receive dose-limited drugs (OR 0.6, 95% CI 0.6–0.7). Other factors associated with either inappropriate drugs or dose limited drugs were white race, psychiatric comorbidity, or receipt of an increasing number of medications.

Busch and colleagues, comparing the quality of pharmacotherapy for patients with major depression in the VA (n=27,713) and private sector (n=4852), found that over 80% of patients received guideline-level acute phase treatment (antidepressant therapy in first 84 days) in either system77. Raw scores showed that VA slightly outperformed the private sector with prescriptions for antidepressants in the initial 84 days (84.7% vs. 81.0%, p<.001) and maintenance phase treatment for 181 days (53.9% vs. 50.9%, p<.001). In the fully adjusted regression models, women patients were more likely to receive guideline level treatment at both 84 (OR 1.18, 95% CI 1.08–1.29) and 181 days (OR 1.14, 95% CI 1.07–1.22). The association of VA care with initial guideline treatment was lost after inclusion of co-morbid diagnoses. No difference was found between VA and private depression care quality in the fully adjusted model.

#### Cardiovascular Risk Reduction and Health Disparities

Nine studies possessed data on cardiovascular risk factors for women veterans, most in the form of prevalence of risk behaviors/conditions or comparisons of process and outcome measures as mentioned above59, 60, 62, 63, 69, 70, 78–80. Frayne et al assessed prevalence of known cardiac risk factors among women veterans who sustained a sexual assault while in the military, and identified obesity, smoking, hazardous alcohol use, sedentary lifestyle, and hysterectomy before age 40 as more common events in women reporting a history of sexual assault in the military compared with women without such as history79. Johnson et al identified watching television more than 2 hours per day and snacking/eating as significantly associated with obesity among women veterans after adjusting for patient characteristics and screening positive for depression or PTSD78. A study by Cypel and colleagues compared a national population based sample of female Vietnam veterans with non-Vietnam veteran cohorts, and found that women Vietnam veterans showed a significant deficit (ARR 0.78, 95% CI 0.62, 0.98) in circulatory system disease relative to non-Vietnam veterans, but significant deficits were also observed when both cohorts were compared with women in the U.S. population (SMR 0.65, 95% CI 0.54, 0.77; SMR 0.82, 95% CI 0.73, 0.93, respectively)80. Additionally, Vietnam veterans were at significantly greater risk of mortality from motor vehicle accidents than non-Vietnam veterans (ARR 2.60, 95% CI 1.22, 5.55) and this appeared to be specific to service in Vietnam based upon comparisons to the U.S. population. While each cardiovascular risk reduction and health disparities study evaluated cardiovascular risk factors or mortality in women veterans, none assessed risk reduction over time or due to specific therapy. The other six articles were mentioned in the sections on general quality of care prevention, processes and outcomes59, 60, 62, 63 and surgical outcomes69, 70.

#### Gender-specific and Reproductive Care

A range of articles of varying quality covered gender-specific and reproductive care issues32, 41, 42, 81–91. Three studies covered deployment related reproductive and pregnancy issues32, 41, 42 and are discussed previously.

One narrative report83 of a VA cognitive behavioral therapy program for transgender women veterans (male to female) showed improvement on measures of anxiety and depression from pre- to post-treatment and appeared to reduce transgender related isolation and stigma. Locating the group in the VA system felt supportive to the veterans who had conceptualized being rejected at a systemic level (e.g., by a government organization). Many transgender specific issues were addressed in this CBT framework, and the work may serve as a road-map for future group and individual therapy.

Two studies involved urological issues in military or veteran patients84, 87. The first study reported that more active duty women with dysuria postponed voiding; reported fluid restriction; were treated for dysuria in the field or after field duty; and used tampons, pads or devices to control urinary incontinence during field duty84. The second study87 described the prevalence of eight high priority urologic diseases among patients in the VA. While no major findings are reported by gender, interstitial cystitis was almost twice as prevalent among female compared to male VA users (2205 vs. 1311 per 100,000 persons). The etiology or context for this finding was not described.

One retrospective pilot study described pregnancy costs and outcomes at a single VA medical center 91. These investigators found that among the 33 pregnancies reviewed, 31% were to women with at least one chronic condition (mainly hypertension and asthma), 39% had at least one psychiatric condition, and 36% had an adverse pregnancy outcome (e.g., premature birth, gestational diabetes, etc). The estimated mean total cost of pregnancy care for the entire sample was $9,359 (range $5,466 to $20,279).

A few studies provided information on sexual health, contraception and hormone therapy81, 86, 88, 90. Among a small group of active duty women completing an anonymous survey on sexual health information, responses yielded little desire for information regarding safer sexual practices86. However, information requested during normal duty differed from information requested for deployment. Information most frequently requested during deployment included how to abstain or say no to sex (23.5%), how to use safer sex or condoms (10.2%), and how to keep oneself clean or personal hygiene (9.2%), whereas no information (14.4%), how to use safer sex or condoms (9.3%), and how to abstain or say no to sex (9.3%) were the top choices for information requested during normal duty.

During 2004–2006, military facilities filled hormonal contraceptive prescriptions for more than half (54.2%) of all females who served in an active component of the US military90. The majority of females who were prescribed hormonal contraceptives were younger than 25 years old (51.2%), white (55%), and not married (56.7%). Females in their twenties were more likely than those younger or older to receive prescriptions for hormonal contraceptives of all types except the IUD with progestin. For latter reproductive years, two studies were present. In a very small study of women at one VA site, over three-quarters stopped taking hormone replacement therapy after the WHI trial reports in 2002, and recurrent vasomotor symptoms were common in those who quit abruptly compared to those who tapered88. Tapering did not appear to reduce the recurrence of vasomotor symptoms. A larger national study completed after the pilot, indicated similar findings with nearly two-thirds of women nationally in VA stopping their hormone therapy within two-years after the WHI trial81.

Women with gender-specific and non-gender specific pain reported had high correlations with psychological stress, lower health status and sometimes trauma. For breast pain, women reporting frequent mastalgia, compared to those without mastalgia, were more likely to screen positive for PTSD, major depression, panic disorder, eating disorders, alcohol misuse, or domestic violence, and often reported fibromyalgia, chronic pelvic pain, or irritable bowel syndrome89. In a study of women veterans with and without menstrual symptoms, data revealed significantly lower scores for nearly all domains of the SF-36 (p<.01), both before and after adjustment for sociodemographic, psychosocial, and comorbidity variables82. Results remained unchanged when analyses were limited only to women without a depression or a sexual trauma history.

Finally, a mammogram intervention trial was evaluated for external and internal validity85. For internal validity, the five study groups did not differ with respect to any of the covariates. Groups not receiving the intervention showed similar rates of mammogram screening during the 1 or 2 years before or after the baseline survey, indicating that cueing had not occurred. Mammogram screening rates during the 30 months prior to the baseline evaluation for 5 different randomized groups of women showed mildly lower screening in group 5 compared to all other groups combined (82.3% vs 85.1%) which was consistent with changes occurring nationally. (The specific trial is discussed at the end of this quality section within the clinical trials subgroup.)

#### Other

Seven articles could not be clustered in the categories above92–98. One study focused on patient perceptions of breast cancer risk susceptibility and found that only breast symptoms and cancer worry predicted greater perceived susceptibility. The models only explained a small amount of variance for each susceptibility measure98. For VA patients on ace inhibitor medications, independent of other factors, risk of angioedema among VA patients was higher for blacks, females, and patients with chronic heart failure or coronary artery disease, but substantially lower for diabetics92. The five following studies had women in their samples and analyses and had no difference identified by gender93, 95–97 and/or did not comment on results or discussions on implications of women in their sample for health status/quality of life comparisons94, 95 or cost comparisons93, 97.

#### Clinical Trials

The last two studies in this section are trials8, 9. One is an educational intervention to improve VA employee perceptions of women veterans. The other is an intervention to increase mammography screening among women veterans.

##### VA Employee Study

The VA employee study by Vogt8 was an educational intervention which evaluated gender role ideology (i.e., “the extent to which a health-care worker does or does not rely on negative stereotypes about women, as they compare to men, to make judgments about different aspects of care”), knowledge, and sensitivity among male and female employees randomly given the educational training then compared with a control group8. Initial findings indicated that older age, direct patient contact, and years of VA employment predicted higher gender awareness and suggested a meaningful role for ”hands-on” experience with veterans. Analyses revealed significantly greater improvement in sensitivity and knowledge for participants in intervention relative to control setting. Contrary to expectations, the program did not significantly improve gender-role ideology.

##### Mammography Intervention

This study by Vernon et al9 was a randomized controlled trial of two interventions in a population-based, nationally representative sample of women veterans that compared rates of completion of two or more mammograms among women assigned to two types of interventions versus a survey only control group. While the absolute between group differences ranges from 3–6%, depending on analyses, neither was superior to the control group.

#### Summary

The satisfaction data are mixed. Women veterans who do not use the VA lack understanding of VA care and services. Among VA users, women and men had similar outpatient satisfaction ratings; however, women had consistently lower ratings for inpatient care. Additionally, women veteran satisfaction was affected by access to women’s clinics, gynecological care, and overall continuity of care. The VA quality assessment indicated that women in VA may have some comparable outcomes with men; however, overall improvement is needed for lipid and hypertension control and preventive immunizations. Surgical data indicate that women in VA settings have equal or lower surgical morbidity and mortality outcomes compared with the private sector for general and vascular procedures. Pharmacy data indicate that while VA has consistently lower or comparable rates of inappropriate prescription drugs in the elderly, and women in the VA (compared to men) are consistently more likely to be prescribed inappropriate drugs by regardless of the criteria used73–76.

Separately, the literature on quality of care and cardiovascular risks in women veterans is salient but small. Women appear to have obesity related surgical outcomes equivalent or better than the non-veteran women, but have higher levels of cardiovascular disorders compared to civilian women and lower level of ambulatory care intermediate outcomes (LDL-cholesterol control) compared to men veterans. None of the epidemiologic or quality of care studies focused on cardiac risk reduction over time or with specific therapies. Studies with intermediate outcomes (e.g., controlled lipids or other process measures) and disease outcomes (lower disease-specific morbidity and mortality rates) are desperately needed to understand what improves cardiovascular care for women veterans alone or in mixed populations with men.

Finally, women veterans with a history of MST and PTSD have increased obesity associated risk factors. This subgroup of studies indicates that cardiovascular risk reduction will be a growing and ongoing need in VA with the growing population of women veterans who will age in our system.

### ACCESS AND UTILIZATION

Forty-eight articles focused on access and utilization addressed determinants of access, gender and utilization, and utilization among special populations – sexual trauma patients, mental health/PTSD patients, and veterans from different periods of military service. Twelve articles focused on determinants of access51, 100–110; fourteen focused on gender-specific care or gender differences and access46, 81, 111–122. Six articles focused on sexual trauma patients and utilization123–128; and eleven focused on PTSD or other mental health patients and utilization15, 129–138. Five additional studies focused on access and utilization among specific cohorts of veterans20, 25, 139–141.

#### General Determinants of Access

The studies on determinants of access to VA care identified knowledge gaps about VA care, incorrect assumptions about services available to women, and difficulty with using VA care as major barriers to women’s using the VA51, 101, 102. Other factors influencing women not to use the VA or to use both the VA and private sector care included availability of private insurance or higher income102–104. Patient and organizational factors related to low VA and non-VA dual use were no insurance, receipt of general gynecological care from the VA provider or use of women’s clinics100, 107. For patients older than 65, availability of Medicare HMOs predicted healthcare use outside the VA110. Among veterans with dual VA-Medicare eligibility, veteran women were more likely than veteran men to rely solely on VA care108, 109. Additionally, one qualitative study found that veterans reported using VA due to cost issues in addition to more access to services (compared to local community) and quality of care available at VA106. These veterans voiced similar concerns about cost, access and quality in other settings if VA outsourced care, with the greatest concerns being whether they would be negative effects (e.g., lower quality, harder to obtain appointments or wait time)106. One last study on utilization after increases in medication copayments among male and female veterans with schizophrenia noted that outpatient visits remained stable, but inpatient admissions increased slightly105.

#### Gender-Specific Differences in Access

Compared with male VA users, women who used VA care had more outpatient encounters111 and also used more outpatient services if they had medical, mental health, or pain conditions in comparison to men111, 112, 115. Women veterans in a Midwestern regional sample were found to have higher health related quality of life compared with men; however, younger women who had poor mental or physical health functioning had fewer primary care visits compared with men with the same characteristics114. A study of total knee replacement or hip arthroplasty in the VA found no gender difference in rates of these surgical procedures117. A smoking cessation study documented that while women and men were equally likely to be advised to quit smoking and be referred to a cessation program, women less often received nicotine patches (OR 0.50, 95% CI 0.3, 0.9) and were less likely to have successfully quit smoking one year later118. For women veterans requiring emergency gynecological or mental health care, VA sites reported high availability during general clinic hours (64.4% and 82.7% respectively had specialty emergency care); however, this access dropped to half or fewer sites offering after hours emergency care for women46. The main predictors for access for a VA site were the presence of a separate women’s health clinic or lower local managed care penetration for emergency mental health.

#### Gender-Specific Differences in Utilization

The gender-specific data covered a broad range of topics. After the Women’s Health Initiative data were reported in 2002 and 2004, women veterans nationally discontinued hormone therapy at about the same rate as non-veteran women. However women utilizing VA women’s clinics more often stayed on hormone therapy compared with women cared for in other VA settings81. Women veterans with spinal cord disorders compared with those without showed higher rates of cardiovascular disease, lower health status, and fewer reports of preventive dental care, colon screening, and mammogram screening, indicating areas for improvement. Rates of vaccinations and lipid screening were similar for these two groups113. With regard to breast disease, image-guided breast biopsies were shown to be more cost-effective compared with traditional open biopsy surgical techniques at one VA site116, and factors inversely affecting demand for mammograms included patient characteristics of older age, poor health and smoking status, and the system factor of increased waiting time for the mammogram119.

LaVela122 also described utilization of services by veterans with spinal cord disorders. Females, older, and non-white veterans (p<.0.000 each), and veterans with a history of medical problems such as respiratory, kidney/urinary tract, circulatory, or digestive system diseases (p<0.005 for each) were more likely to use outpatient care, and farther distance from VA facilities indicated infrequent use (p<0.000). Homeless female veterans were more likely to receive compensation benefits rather than pension benefits 120. In the limited number of veterans (15%) who were subsequently awarded benefits; they were more likely to have reported recent use of VA services and a greater number of medical and psychiatric problems at the time of outreach120. Finally, a convenience sample of women veterans at one VA site121 showed that women veterans with pain (vs. without) were more than 6 times as likely to report ≥12 medical visits in the past year and twice as likely to report ≥12 visits to a mental health provider.

#### Sexual Trauma and Utilization

The research on sexual trauma and utilization revealed patient difficulties with identifying their emotions124, more use of VA services among those with sexual trauma histories125, 128, and more psychological impairment compared with veterans with other forms of trauma126, 128. In addition, women who had experienced more severe forms of sexual violence in the military (i.e., repeated rapes or gang rapes) were severely impaired physically and emotionally compared with women who had no or one such event, and were more likely to use both inpatient and outpatient mental health services127. A national study of veterans screened for military sexual trauma showed that both men and women who had a positive screen were more than twice as likely to have a post-screen mental health visit compared with those who screened negative123, a benefit for both genders in the VA.

#### PTSD and Other Mental Health Issues

Among the eleven PTSD and mental health studies focused on utilization15, 129–138, women with PTSD symptoms and women with other mental health issues were more likely to use VA services compared with women without PTSD symptoms or men, respectively129, 138. Other gender-related findings were that being mistreated as a child did not appear to be associated with increased utilization among women with PTSD133. Both women veterans with PTSD and female partners of Vietnam Veterans with PTSD preferred treatment or support services that were female-only135, 136. One study examined continuity of care and treatment outcomes but was not able to find a significant association between continuity of care factors and PTSD outcomes when analyses were adjusted for multiple comparisons137. Compared to men with mental illness, women with mental health issues were less likely to be placed in nursing home settings132. Identification of patients by psychiatric criteria on interview indicated that up to 44% of women veterans in primary care may have at least 1 mental health diagnosis130, and middle age adults are more likely to have a psychiatric diagnosis compared with younger and older veterans131. One article noted that patients with mental health diagnoses (compared to those without mental illness) are less likely to be screened for lipid disorders unless they have increased outpatient utilization at the VA134. A last study focusing on OEF/OIF veterans with PTSD is discussed in a previous section15.

#### Access and Utilization Among Specific Cohorts

Several access and utilization studies focused on specific cohorts of military personnel. One study noted that active duty Air Force personnel who self-refer for mental health services compared with those referred by supervisors are less likely to have a significant diagnosis, have confidentiality broken, or have career-affecting recommendations made 140. For women Vietnam veterans, physical health problems mediated the relationship between combat exposure and outpatient utilization for physical health, whereas combat exposure only indirectly predicted men’s mental healthcare use 139. The Iowa Gulf War Study identified similar combat and noncombat exposures among men and women but noted that women were more likely to report more than 5 outpatient visits in the prior year, and inpatient hospitalization, and receive VA compensation141. Two other studies focused on OEF/OIF personnel and were discussed previously20, 25.

#### Summary

Women with positive screens for mental health disorders, trauma, or diagnoses tend to use more healthcare services than women without positive screens or than men veterans. In a few areas, findings are mixed, cautioning us to remain aware of patients who may reduce utilization because of specific mental health issues.

### PSYCHIATRIC CONDITIONS

The 85 publications covering mental health and psychiatric issues fell into five broad categories: PTSD5–7, 13, 15, 22, 23, 26, 28, 55, 58, 129, 131, 133, 135–137, 142–166; substance abuse and treatment167–171; general mental health130, 132, 134, 138, 140, 172–179; Trauma10, 124, 128, 180–194; and other77, 105, 195–199. The PTSD focused articles included screening and treatment, descriptors and determinants of diagnosis, quality of life and utilization impacts, and comorbid disorders. General mental health articles included prevention and screening, deployment issues, quality of life, and utilization.

#### PTSD

##### Clinical Trials

Three PTSD clinical trials focused on treatment occurred during this period5–7. David evaluated a 12-week open behavioral intervention for PTSD patients5. The intervention focused on structured group psychotherapy and self-defense training and measured patient risk perceptions among women veterans with PTSD. Women veterans showed significant and sustained-gram with respect to PTSD avoidance behavior and hyperarousal symptoms. Patients also had decreased depression scores, and increased interpersonal self-efficacy, self defense self-efficacy and willingness to participate in community activities. Schnurr et al. was a multi-site trial that randomized women veterans and female military personnel with PTSD to either prolonged exposure therapy or present-centered therapy by standard protocol for 10 weeks6. This study indicated that prolonged exposure therapy was significantly associated with a greater reduction of PTSD symptoms and a lower likelihood of meeting PTSD diagnostic criteria after therapy was completed. A final pilot trial by Butterfield et al. evaluated olanzapine therapy over 10 weeks in a small, double blind, placebo controlled group of patients (predominantly female) with non-combat related PTSD and reported no between-group difference in treatment responses but noted a large placebo effect7.

##### Screening and Symptoms

PTSD screening and treatment included seven articles covering a variety of topics26, 28, 135, 137, 142–144. One study found that a small subset of veterans (2.7%) filing disability benefits for PTSD reported being spontaneously distressed by a survey 142. However, in a Persian Gulf War I cohort, gender analyses revealed that perceived threat was associated with more PTSD type symptoms for National Guard/Reserve men compared with active duty men, but the PTSD symptom associations were greater for active duty women compared with women in guard/reserve units143. Another gender related finding was that the most important factor for women veterans and partners of disabled veterans coming to the VA for PTSD treatment was the availability of specialized treatment programs for women135.

Women veterans treated for PTSD with group psychoeducation and self-defense training showed (similar to the David 2006 study5) improved use of personal safety skills144. Lambert’s case series on the use of aripiprazole with either sertraline or cognitive –behavior therapy shows some promise in improving symptoms in some patients26. Corrections for multiple comparisons eliminated the relationships between clinical status outcomes and continuity of care in a small sample of women receiving outpatient VA treatment for PTSD137. Future clinical trials will be needed to produce clinical evidence for improving PTSD symptoms in women through medication and therapy.

Finally, the findings of the repeat post-deployment screens for PTSD and other symptoms among OEF/OIF veterans are discussed in an earlier section28.

##### Determinants of Diagnosis

Twelve articles focused on determinants of a diagnosis22, 23, 133, 145–153. In a study of stress and social support among male and female Marine recruits, the negative impact of stress reactions on hardiness (i.e., courage and motivation to cope with stressors in daily life) was strongest when social support was low; however, in women stress reactions predicted enhanced hardiness when social support was high145. Women who have strong social supports may endure more stressors without negative consequences. In a similar fashion, life experiences and unit cohesion predicted PTSD symptoms in active duty soldiers, with unit cohesion appearing to ameliorate some life experiences and symptoms153. A few studies focused on the determinants of PTSD found the following associations: 1) poorer perceptions of health and well being were correlated with increased depression or PTSD symptoms146; 2) PTSD diagnosis and symptoms were associated with more medical conditions and poorer health related quality of life151, and gender did not moderate the relationship between PTSD and poorer health related quality of life147; 3) one VA primary care clinic identified PTSD as the best predictor for somatization in women patients148; and 4) pain related factors149, childhood non-sexual/physical maltreatment, childhood sexual assault152 or adult sexual assault133, 150 were significant predictors of PTSD symptom clusters among women veterans. Two other studies are discussed previously in the deployment and post-deployment health section22, 23.

##### Quality of Life and PTSD

Fifteen articles focused on quality of life and mental health13, 15, 55, 58, 129, 131, 136, 154–161. Findings varied in mixed gender versus single gender studies. Among male and female veterans treated for PTSD in the VA, overall quality of life was poor and did not differ between genders, and numbing was uniquely associated with reduced quality of life154. In contrast, women screening positive for PTSD symptoms (compared to those screening negative) had more mental and physical problems, and poorer health related quality of life160.

Two studies examined how PTSD-related stress affects the family of veterans155, 156. Severity of PTSD symptoms was negatively correlated with marital adjustment (r=−.38), family adaptability (r=−.40), cohesion (r=−.34) and parenting satisfaction (r=−.31)155. Among women Vietnam veterans, hyperarousal symptoms negatively impacted parenting satisfaction156. Gahm et al. identified family experiences that may contribute to PTSD risk161. Experiencing combat (OR 2.04), witnessing someone being assaulted or killed (OR 1.88), and number of adverse childhood events (OR 1.25) all emerged as significant risk factors for PTSD symptoms161. In a PTSD disability benefits study, regional differences in PTSD awards are not explained by different PTSD symptom severity or level of disability159. Separately, no difference in the reporting of low income occurs among women compared to men applying for PTSD disability benefits157. In addition, a disparity in estimated rates of service connection for PTSD by gender was partially explained by differences in combat exposure158. A number of related articles were discussed under postdeployment OEF/OIF health13, 15 and PTSD symptoms related to access and utilization129, 131, 136.

Satisfaction had mixed associations with PTSD symptoms55, 58. Women veterans with trauma related mental health symptoms reported more satisfaction with overall primary care and their provider55. However, in another study patients with PTSD and other co-morbid diagnoses reported lower overall satisfaction with primary care (see Desai (2005) discussion under quality of care and patient satisfaction)58.

##### Comorbid Disorders

A few articles covered co-morbid disorders162–166. Women with PTSD had more medical conditions and worse health status than women with only depression or neither diagnosis162. Among a male and female cohort of Persian Gulf military followed longitudinally, a drug problem or PTSD symptoms at time point 2 was predictive of a positive drug use screen at time point 3 but not predictive of alcohol use163. African American female veterans at one VA site had a greater prevalence of prior exposure to violence (childhood or adult sexual abuse, intimate partner violence or sexual harassment) than their Caucasian counterparts, but these levels were not markedly different from other low-income African American women164. In another single site VA study of women veterans, women with a history of MST had a greater odds of PTSD (OR 4.4, 95% CI 2.4, 8.2), but prior experience of other trauma was not a significant predictor of PTSD (OR 1.3, 95% CI 0.63, 2.5)165. A similar analysis revealed that the relative risk of women with MST developing PTSD was nearly 2.5 times that of patients without MST (RR 2.40)166.

#### Substance Abuse and Treatment

Five studies explored substance abuse issues in military and veteran populations167–171. Two169, 170 describe military and veteran characteristics associated with alcohol use, while the others describe predictors for participating in substance abuse treatment programs167, 168, 171.

Gutierrez and researchers169 assessed alcohol behaviors among deployed soldiers (within and outside of the United States) in 2003 and found that significant predictors of greater alcohol-related consequences, as assessed with the CAGE questionnaire, included less formal education, male gender, not being in an intimate relationship, racial/ethnic minority status, enlisted rank, having been deployed to the continental United States, and greater stress [χ^2^(8,5,458) = 235.991; p < 0.001]. Lande et al170 determined gender based differences in alcohol use among Army soldiers and noted that although men were more likely to engage in “bolus” (binge) drinking, women exceeded established guidelines for safe alcohol consumption (i.e., 7 drinks per week) at a risk-adjusted rate nearly twice that of men. In addition, for individuals whose behaviors were considered unsafe, the severity of reported negative consequences was influenced by gender. Women initially experience greater psychosocial impairment, and—should harmful drinking patterns progress to alcohol dependency – they are at greater risk of injury, morbidity, and mortality than men.

Predictors of admission into a substance abuse treatment program for active duty women include coexisting psychiatric conditions171, primarily concurrent use of alcohol171 and for veteran women in intensive outpatient treatment include cocaine abuse/dependence, greater burden of medical and psychiatric co-morbidities compared to men in intensive treatment and compared to other women veterans not in treatment167. For homeless veterans, the situation is more complicated. Benda168 compared readmission rates for substance abuse program by gender among homeless veterans and identified abuse in childhood, during military status or in the recent 2 year period prior to admission were all potent factors for women compared to men. Readmission for women was heightened by increases in depression, suicidal thoughts or traumatic events, while for men it was increased by elevated substance abuse, aggression and cognitive impairment. However, social supports through family, friends, church or other mechanism all lessened readmission rates for women, while employment stability and job satisfaction reduced the readmissions for men.

#### General Mental Health

The general mental health prevention and screening articles indicated that women in the military had a higher prevalence of mental health disorders such as panic, anxiety and depression compared with men in the military175, 176. The exception is alcohol abuse, where the prevalence among men in active duty cohorts was higher than that of military women175.

##### Quality of Life

For veterans responding to the Large Health Survey of Veteran Enrollees in 1999, Physical and mental component scores were similar by gender except among those age 65 or older, where mean MCS was better for women than men (49.3 vs 45.9, p<.001)179. Among women veterans, health related quality of life physical component scores were lower, with more limitations in activities of daily living and more reported pain than the men172, and among psychiatric patients, rural veterans had worse physical component scores and mental component scores compared to urban-dwelling veterans173. Those with mental health comorbidities also had lower health related quality of life scores174. Women in the Air Force showed increased levels of family stress, work family conflicts and job distress compared with community samples of women177, and children of deployed Air Force mothers in Operation Desert Storm were at risk for multiple behavioral and emotional adjustments problems178.

##### Utilization

Within VA primary care clinics, a large proportion of women (44%) had at least one mental health diagnosis, and about 40% of these women with a mental health condition received care in a VA specialized mental health clinic130. Service members discharged from the military for mental health reasons were more likely to use VA mental health services if they were women, older, or had schizophrenia or bipolar disorder. The women were more likely to contact VA and use VA services compared with the men138. Within the military, service members who self-referred for mental health care had better outcomes than those members who had been referred to mental health care by their supervisor140. Other articles discussed previously included nursing home users were likely to be men, recently hospitalized and with dementia132, and lipid screening was low for veterans who used VA mental health services infrequently but increased screening occurred with increased levels of outpatient use134.

#### Trauma

##### General Sexual Trauma or MST

Key findings from the nine articles on general sexual trauma or MST10, 124, 128, 180–185 include the following: Positive MST screens among women and men were associated with greater odds of nearly all mental health comorbidities, including PTSD in women (OR 8.83, 99% CI 8.34, 9.35) and men (OR 3.00, 99% CI 2.89, 3.12), but were almost three times stronger among women180. These findings were reinforced in an additional study evaluating the various forms of sexual assault and PTSD diagnosis183 and in one of the OEF/OIF deployment studies discussed previously10. In-service sexual harassment severity was also associated with PTSD symptom severity in women, after adjusting for other reported traumas185. Many active duty women (80%) and men (45%) reported at least one type of sexual stressor in the previous year (i.e., sexual identity challenges, sexual harassment, or sexual assault)181. In addition, women with a history of sexual trauma report significantly higher levels of anxiety for any gender-specific or invasive exams (breast, pelvic, rectal) when the clinician is male (p<.001 for each exam)182. Moreover, women with sexual trauma histories showed evidence of alexithymia (i.e., difficulty identifying one’s emotions), and this factor explained variance in both physical health and urgent care utilization among these women124. Notably, a small study of women with physical and/or sexual assault histories reported that self-defense training would be an effective addition to traditional treatments for PTSD184. An additional relevant article is discussed in the access and utilization section128.

##### Trauma from Multiple Sources

Women experiencing multiple traumatic events (sexual, physical or both) during military service, had more severely impacted health status190, 194 and more outpatient visits190. Some women had repeated violent experiences from childhood which were also associated with worse physical and mental quality of life compared to women without the history189; other childhood events were more frequently perpetrated by parental figures, occurred over longer durations or involved more severe experiences of abuse186. Prior to entering the military, one-fourth of recruits reported pre-military physical intimate partner violence (IPV) events191 and both physical IPV and history of interpersonal trauma predicted attrition from the military187, 191. Separately, active duty women’s perceptions of screening for domestic violence (now called intimate partner violence) in the military was generally supportive, but fewer women thought abuse should be reported to the commanding officer192.

Multiple workplace factors increased the likelihood of physical assault for women in the military: experiencing unwanted sexual advances or pressure for dates in sleeping quarters (7 fold); experiencing hostile work environments (5 fold); observing heterosexual activities in sleeping quarters (4 fold); and ranking officers making sexually demeaning comments or behaviors (3 fold)193. Of note, being quartered in mixed gender barracks was not significantly associated with physical assault. Combat and non-combat exposed veterans had different levels of sexual assault in-service; higher levels occurred among non-combat males (13% vs 6%) and non-combat females (75% vs 63%) for unclear reasons188.

#### Other

The other mental health articles focused on other psychiatric conditions not discussed previously. Three articles focused on depression treatment77, 197, 199. The first showed no difference in depression therapy between VA and the private sector77, the second identified depression screening rates of nearly 85% in 2002, but only about half the patients received follow up if they screened positive and male gender was a factor197. The third article found that among depressed veterans, being young, male, and white were the demographic factors associated with higher suicide risks199. However, the relative risk ratio for suicide among men compared with women was smaller than in the general population. The remaining four articles identified that 60% of veterans with serious mental illness had overwhelmingly poor dental health195; bipolar disorder patients who were nonadherent to medication were likely to have an active substance use disorder such as alcohol abuse196, with women showing higher odds of nonadherence198; and lastly, psychiatric drug refills dropped nearly 25% among schizophrenia patients after copayments for medications increased105.

The remaining articles from on psychiatric conditions were included in the access and utilization section covering mental health issues, deployment and post-deployment health section for OEF/OIF veterans and non OEF/OIF veterans.

#### Summary

The section on psychiatric conditions covers a broad spectrum of literature describing issues for women and men veterans. This literature should provide a stable foundation for increasing treatment and outcome pilot and multi-center trial studies among women veterans.

Three points should be emphasized.

- More clinical trials like those of David, Schnurr, and Butterfield are needed to help direct VA providers toward treatment options that are best suited for the female veteran patient.
- The literature confirms the positive relationship between MST and PTSD, and both of these diagnoses have multiple negative health-related associations that both providers and policymakers need to understand. In particular, women with a sexual trauma history reported significant anxiety for any invasive exam and male providers. Such data are critical for managing patients in primary care where repeated invasive exams (breast, pelvic, rectal) will be required to provide evidence-based quality care over the life span; the role of provider type and practice setting (women’s clinics) may be a long-term issue.
- A small cluster of studies show that social support (in military or in civilian life) may be a factor for resiliency and quality of life among women and (possibly their children) while performing in the military and when they transition home from deployment.