# REFERENCES

1 Goldzweig CL, et al. The State of Women Veterans’ Health Research. Journal of General Internal Medicine. 2006;21:S82-S92. [pmid: 16637952].
2 Hayes P, Krauthamer M. Changing the face of health care for women veterans. Federal Practitioner. 2009;26(2):8-10.
3 Brix K. Bean-Mayberry B, editor. RE: Women Veteran Literature Request. 2008. Los Angeles.
4 Jadad AR, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
5 David WS, Simpson TL, Cotton AJ. Taking charge: a pilot curriculum of self-defense and personal safety training for female veterans with PTSD because of military sexual trauma. J Interpers Violence. 2006;21(4):555-65. [pmid: 16501219].
6 Schnurr PS, et al. Cognitive Behavioral Therapy for Posttraumatic Stress Disorder in Women. JAMA. 2007:297.
7 Butterfield MI, et al. Olanzapine in the treatment of post-traumatic stress disorder: a pilot study. International Clinical Psychopharmacology. 2001;16(4):197-203. [pmid: 11459333].
8 Vogt DS, Barry AA, King LA. Toward Gender-Aware Health Care: Evaluation of an Intervention to Enhance Care for Female Patients in the VA Setting. Journal of Health Psychology. 2008;13(5):624-638. [pmid: 18519436].
9 Vernon SW, et al. Promoting regular mammography screening II: Results from a randomized controlled trial in US women veterans. J Natl Cancer Inst. 2008;100:347-358. [pmid: 18314474].
10 Smith TC, et al. Prior assault and posttraumatic stress disorder after combat deployment. Epidemiology. 2008;19:505-512. [pmid: 18414091].
11 Felker B, et al. Characteristics of deployed Operation Iraqi Freedom military personnel who seek mental health care. Mil Med. 2008;173(2):155-8. [pmid: 18333491].
12 Seal KH, et al. Bringing the war back home: mental health disorders among 103,788 US veterans returning from Iraq and Afghanistan seen at Department of Veterans Affairs facilities. Arch Intern Med. 2007;167(5):476-82. [pmid: 17353495].
13 Hoge CW, et al. Association of posttraumatic stress disorder with somatic symptoms, health care visits, and absenteeism among Iraq war veterans. Am J Psychiatry. 2007;164(1):150-3. [pmid: 17202557].
14 Helmer DA, et al. Health and exposure concerns of veterans deployed to Iraq and Afghanistan. J Occup Environ Med. 2007;49(5):475-80. [pmid: 17495689].
15 Erbes C, et al. Post-traumatic stress disorder and service utilization in a sample of service members from Iraq and Afghanistan. Mil Med. 2007;172(4):359-63. [pmid: 17484303].
16 Katz LS, et al. Women who served in Iraq seeking mental health services: Relationships between military sexual trauma, symptoms, and readjustment. Psychological Services. 2007;4(4):239-249.
17 Hoge CW, et al. Combat duty in Iraq and Afghanistan, mental health problems, and barriers to care. N Engl J Med. 2004;351(1):13-22. [pmid: 15229303].
18 Stetz MC, et al. Psychiatric diagnoses as a cause of medical evacuation. Aviat Space Environ Med. 2005;76(7 Suppl):C15-20. [pmid: 16018324].
19 Rundell JR. Demographics of and diagnoses in Operation Enduring Freedom and Operation Iraqi Freedom personnel who were psychiatrically evacuated from the theater of operations. Gen Hosp Psychiatry. 2006;28(4):352-6. [pmid: 16814636].
20 Hoge CW, Auchterlonie JL, Milliken CS. Mental health problems, use of mental health services, and attrition from military service after returning from deployment to Iraq or Afghanistan. JAMA. 2006;295(9):1023-32. [pmid: 16507803].
21 Mental health encounters and diagnoses following deployment to Iraq and/or Afghanistan, US Armed Forces, 2001–2006. Medical Surveillance Monthly Report. 2007;14(4):2-8.
22 Lapierre CB, Schwegler AF, Labauve BJ. Posttraumatic stress and depression symptoms in soldiers returning from combat operations in Iraq and Afghanistan. J Trauma Stress. 2007;20(6):933-43. [pmid: 18157882].
23 Smith TC, et al. New onset and persistent symptoms of post-traumatic stress disorder self reported after deployment and combat exposures: prospective population based US military cohort study. BMJ. 2008;336(7640):366-71. [pmid: 18198395].
24 Seal KH, et al. Getting beyond “Don’t ask; don’t tell”: an evaluation of US Veterans Administration postdeployment mental health screening of veterans returning from Iraq and Afghanistan. Am J Public Health. 2008;98(4):714-20. [pmid: 18309130].
25 McNulty PA. Reported stressors and health care needs of active duty Navy personnel during three phases of deployment in support of the war in Iraq. Mil Med. 2005;170(6):530-5. [pmid: 16001607].
26 Lambert MT. Aripiprazole in the management of post-traumatic stress disorder symptoms in returning Global War on Terrorism veterans. Int Clin Psychopharmacol. 2006;21(3):185-7. [pmid: 16528142].
27 Stecker T, et al. An assessment of beliefs about mental health care among veterans who served in Iraq. Psychiatr Serv. 2007;58(10):1358-61. [pmid: 17914017].
28 Routine screening and referrals for Post-Traumatic Stress Disorder (PTSD) after returning from Operation Iraqi Freedom in 2005, US Armed Forces. Medical Surveillance Monthly Report. 2007;14(6):2-7.
29 Farley JH, et al. Far forward gynecologic care of the female soldier. J Reprod Med. 2006;51(1):31-5. [pmid: 16482774].
30 Thomson BA, Nielsen PE. Women’s health care in Operation Iraqi Freedom: a survey of camps with echelon I or II facilities. Mil Med. 2006;171(3):216-9. [pmid: 16602519].
31 Vogt DS. Validation of Scales From the Deployment Risk and Resilience Inventory in a Sample of Operation Iraqi Freedom Veterans. Assessment. 2008;15(4):391-403. [pmid: 18436857].
32 Haas DM, Pazdernik LA. Partner deployment and stress in pregnant women. J Reprod Med. 2007;52(10):901-6. [pmid: 17977163].
33 Adler AB, et al. The impact of deployment length and experience on the well-being of male and female soldiers. J Occup Health Psychol. 2005;10:121-37. [pmid: 15826223].
34 Vogt DS, et al. Deployment Stressors, Gender, and Mental Health Outcomes Among Gulf War I Veterans. Journal of Traumatic Stress. 2005;18(3):272-284. [pmid: 16281224].
35 Lindstrom KE, et al. The mental health of U.S. military women in combat support occupations. J Womens Health (Larchmt). 2006;15(2):162-72. [pmid: 16536680].
36 Cavin S. World War II Never Ended in My House: Interviews of 12 Office of Strategic Services Veterans of Wartime Espionage on the 50th Anniversary of WW II. Psychobiology of posttraumatic stress disorders: A decade of progress (Vol. 1071). 547 Blackwell Publishing. Malden, MA Malden, MA. 2006;xxiii:463-471.
37 Wolfe J, Brown PJ, Bucsela ML. Symptom responses of female Vietnam veterans to Operation Desert Storm. Am J Psychiatry. 1992;149(5):676-9. [pmid: 1497718].
38 Smith TC, et al. The physical and mental health of a large military cohort: baseline functional health status of the Millennium Cohort. Bmc Public Health. 2007:7. [pmid: 17233919].
39 Pierce PF. Physical and emotional health of Gulf War veteran women. Aviat Space Environ Med. 1997;68(4):317-21. [pmid: 9096828].
40 Smith TC, et al. The occupational role of women in military service: validation of occupation and prevalence of exposures in the Millennium Cohort Study. Int J Environ Health Res. 2007;17(4):271-84. [pmid: 17613091].
41 Araneta MR, et al. Conception and pregnancy during the Persian Gulf War: the risk to women veterans. Ann Epidemiol. 2004;14(2):109-16. [pmid: 15018883].
42 Pierce PF, Antonakos C, Deroba BA. Health care utilization and satisfaction concerning gender-specific health problems among military women. Mil Med. 1999;164(2):98-102. [pmid: 10050564].
43 Bean-Mayberry BA, et al. Organizational characteristics associated with the availability of women’s health clinics for primary care in the Veterans Health Administration. Military Medicine. 2007;172(8):824-8. [pmid: 17803073].
44 Seelig MD, et al. Availability of gynecologic services in the Department of Veterans Affairs. Womens Health Issues. 2008;18(3):167-73. [pmid: 18329895].
45 Bean-Mayberry BA, et al. Federally Funded Comprehensive Women’s Health Centers: Leading Innovation in Women’s Healthcare Delivery. Journal of Women’s Health. 2007;16(9):1281-1290.
46 Washington DL, et al. VA emergency health care for women: condition--critical or stable?. Womens Health Issues. 2006;16(3):133-8. [pmid: 16765289].
47 Cope JR, et al. Determinants of contraceptive availability at medical facilities in the Department of Veterans Affairs. J Gen Intern Med. 2006;21(Suppl 3):S33-9. [pmid: 16637943].
48 Hall ME, et al. Military sexual trauma services for women veterans in the Veterans Health Administration: The patient-care practice environment and perceived organizational support. Psychological Services. 2007;4(4):229-238.
49 Yano EM, et al. Diffusion of Innovation in Women’s Health Care Delivery: The Department of Veterans Affairs’ Adoption of Women’s Health Clinics. Women’s Health Issues. 2006;16:226-235. [pmid: 17055375].
50 Bean-Mayberry B, Chang CC, Scholle SH. Brief Report: Lack of a Race Effect in Primary Care Ratings among Women Veterans. Journal of General Internal Medicine. 2006;21(10):1105-1108. [pmid: 16970560].
51 Washington DL, et al. Women Veterans’ Perceptions and Decision-Making about VA Health Care. Military Medicine. 2007.
52 Bean-Mayberry BA, et al. Patient Satisfaction in Women’s Clinics Versus Traditional Primary Care Clinics in the Veterans Administration. Journal of General Internal Medicine. 2003;18:175-181. [pmid: 12648248].
53 Wright SM, et al. Patient satisfaction of female and male users of Veterans Health Administration services. J Gen Intern Med. 2006;21(Suppl 3):S26-32. [pmid: 16637941].
54 Bean-Mayberry BA, et al. Ensuring high-quality primary care for women: predictors of success. Womens Health Issues. 2006;16(1):22-9. [pmid: 16487921].
55 Lang AJ, et al. Mental health and satisfaction with primary health care in female patients. Womens Health Issues. 2005;15(2):73-9. [pmid: 15767197].
56 Harriott EM, Williams TV, Peterson MR. Childbearing in U.S. military hospitals: dimensions of care affecting women’s perceptions of quality and satisfaction. Birth. 2005;32(1):4-10. [pmid: 15725199].
57 Fan VS, et al. Continuity of care and other determinants of patient satisfaction with primary care. J Gen Intern Med. 2005;20(3):226-33. [pmid: 15836525].
58 Desai RA, Stefanovics EA, Rosenheck RA. The role of psychiatric diagnosis in satisfaction with primary care: data from the department of veterans affairs. Med Care. 2005;43(12):1208-16. [pmid: 16299432].
59 Tseng CL, et al. Are there gender differences in diabetes care among veterans?. Journal of General Internal Medicine. 2006;21(S3):S47-53. [pmid: 16637945].
60 Tseng CL, et al. Diabetes care among veteran women with disability. Womens Health Issues. 2006;16(6):361-71. [pmid: 17188219].
61 Etzioni DA, et al. Measuring the quality of colorectal cancer screening: the importance of follow-up. Dis Colon Rectum. 2006;49(7):1002-10. [pmid: 16673056].
62 Jha AK, et al. Quality of ambulatory care for women and men in the Veterans Affairs Health Care System. J Gen Intern Med. 2005;20(8):762-5. [pmid: 16050889].
63 Korthuis PT, et al. Lipid screening in HIV-infected veterans. J Acquir Immune Defic Syndr. 2004;35(3):253-60. [pmid: 15076239].
64 Katzburg JR, et al. Listen to the consumer: designing a tailored smoking-cessation program for women. Substance Use & Misuse. 2008;43(8–9):1240-1259. [pmid: 18649241].
65 Katzburg JR, et al. Combining Women’s Preferences & Expert Advice to Design a Tailored Smoking Cessation Program. Subst Use Misuse. 2009;44(14):2114-37. [pmid: 20001698].
66 Friedemann-Sanchez G, Griffin JM, Partin MR. Gender differences in colorectal cancer screening barriers and information needs. Health Expect. 2007;10(2):148-60. [pmid: 17524008].
67 Straits-Troster KA, et al. Racial/ethnic differences in influenza vaccination in the Veterans Affairs Healthcare System. Am J Prev Med. 2006;31(5):375-82. [pmid: 17046408].
68 Vander Weg M, et al. Prevalence of alternative forms of tobacco use in a population of young adult military recruits. Addictive Behaviors. 2008;33(1):69-82. [pmid: 17706889].
69 Johnson RG, et al. Comparison of Risk-Adjusted 30-Day Postoperative Mortality and Morbidity in Department of Veterans Affairs Hospitals and Selected University Medical Centers: Vascular Surgical Operations in Women. Journal of American College of Surgeons. 2007;204:1137-1146.
70 Lautz DB, et al. Bariatric operations in Veterans Affairs and selected university medical centers: results of the patient safety in surgery study. J Am Coll Surg. 2007;204(6):1261-72. [pmid: 17544084].
71 Fink AS, et al. Comparison of risk-adjusted 30-day postoperative mortality and morbidity in Department of Veterans Affairs hospitals and selected university medical centers: general surgical operations in women. J Am Coll Surg. 2007;204(6):1127-36. [pmid: 17544071].
72 Hynes DM, et al. Breast cancer surgery trends and outcomes: results from a National Department of Veterans Affairs study. J Am Coll Surg. 2004;198(5):707-16. [pmid: 15110803].
73 Bierman AS, et al. Sex differences in inappropriate prescribing among elderly veterans. Am J Geriatr Pharmacother. 2007;5(2):147-61. [pmid: 17719517].
74 Pugh MJ, et al. Assessing potentially inappropriate prescribing in the elderly Veterans Affairs population using the HEDIS 2006 quality measure. J Manag Care Pharm. 2006;12(7):537-45. [pmid: 16981799].
75 Barnett MJ, et al. Comparison of rates of potentially inappropriate medication use according to the Zhan criteria for VA versus private sector medicare HMOs. J Manag Care Pharm. 2006;12(5):362-70. [pmid: 16792442].
76 Pugh MJ, et al. Potentially inappropriate prescribing in elderly veterans: are we using the wrong drug, wrong dose, or wrong duration?. J Am Geriatr Soc. 2005;53(8):1282-9. [pmid: 16078952].
77 Busch SH, Leslie DL, Rosenheck RA. Comparing the quality of antidepressant pharmacotherapy in the Department of Veterans Affairs and the private sector. Psychiatr Serv. 2004;55(12):1386-91. [pmid: 15572566].
78 Johnson KM, Nelson KM, Bradley KA. Television Viewing Practices and Obesity Among Women Veterans. Journal of General Internal Medicine. 2006;21:S76-81. [pmid: 16637951].
79 Frayne S, et al. Sexual assault while in the military: Violence as a predictor of cardiac risk?. Violence & Victims. 2003;18(2):219-225. [pmid: 12816405].
80 Cypel Y, Kang H. Mortality patterns among women Vietnam-era veterans: Results of a retrospective cohort study. Annals of Epidemiology. 2008;18(3):244-252. [pmid: 18280922].
81 Haskell SG, et al. Determinants of Hormone Therapy Discontinuation among Female Veterans Nationally. Military Medicine. 2008;173(1):91-6. [pmid: 18251338].
82 Barnard K, et al. Health status among women veterans with menstrual symptoms. Journal of Women’s Health. 2003;12(9):911-920.
83 Maguen S, Shipherd JC, Harris HN. Providing Culturally Sensitive Care for Transgender Patients. Cognitive and Behavioral Practice. 2005;12:479-490.
84 Albright TS, et al. Acute Dysuria among Female Soldiers. Military Medicine. 2005;170(9):735-738. [pmid: 16261975].
85 del Junco DJ, et al. Promoting regular mammography screening I. A systematic assessment of validity in a randomized trial. J Natl Cancer Inst. 2008;100(5):333-46. [pmid: 18314473].
86 von Sadovszky V, Ryan-Wenger N. Army women’s sexual health information needs. J Obstet Gynecol Neonatal Nurs. 2007;36(4):348-57.
87 Sohn MW, et al. Prevalence and trends of selected urologic conditions for VA health-care users. BMC Urol. 2006;6:30. [pmid: 17083728].
88 Haskell SG. After the Women’s Health Initiative: Postmenopausal women’s experiences with discontinuing estrogen replacement therapy. J Womens Health (Larchmt). 2004;13(4):438-42. [pmid: 15186661].
89 Johnson KM, et al. Frequency of mastalgia among women veterans: Association with psychiatric conditions and unexplained pain syndromes. Journal of General Internal Medicine Improving health care for women veterans. 2006;21(Suppl 3):S70-S75.
90 Hormonal contraceptive use among female service members, active components, U.S. Armed Forces, January 2004-March 2006. Medical Surveillance Monthly Report. 2007;14(7):9-13.
91 Chireau MV, et al. Outcomes, costs, and utilization of pregnancy related care. Federal Practitioner. 2006:20-30.
92 Miller DR, et al. Angioedema incidence in US veterans initiating angiotensin-converting enzyme inhibitors. Hypertension. 2008;51(6):1624-30. [pmid: 18413488].
93 Yu W, Wagner TH, Barnett PG. Determinants of cost among people who died in VA nursing homes. Med Care Res Rev. 2006;63(4):477-98. [pmid: 16847074].
94 Weeks WB, et al. Rural-urban disparities in health-related quality of life within disease categories of Veterans. J Rural Health. 2006;22(3):204-11. [pmid: 16824163].
95 Mrus JM, et al. Health-related quality of life in veterans and nonveterans with HIV/AIDS. J Gen Intern Med. 2006;21(Suppl 5):S39-47. [pmid: 17083499].
96 McEachrane-Gross FP, Liebschutz JM, Berlowitz D. Use of selected complementary and alternative medicine (CAM) treatments in veterans with cancer or chronic pain: a cross-sectional survey. BMC Complement Altern Med. 2006;6:34. [pmid: 17026768].
97 Maciejewski ML, et al. The performance of administrative and self-reported measures for risk adjustment of Veterans Affairs expenditures. Health Serv Res. 2005;40(3):887-904. [pmid: 15960696].
98 McQueen A, et al. Predictors of perceived susceptibility of breast cancer and changes over time: a mixed modeling approach. Health Psychol. 2008;27(1):68-77. [pmid: 18230016].
99 Fick DM, et al. Updating the Beers criteria for potentially inappropriate medication use in older adults: results of a US consensus panel of experts. Arch Intern Med. 2003;163(22):2716-24. [pmid: 14662625].
100 Bean-Mayberry B, et al. Comprehensive Care for Women Veterans: Indicators of Dual Use of VA and non-VA Providers. Journal of American Medical Women’s Association. 2004;59(3):192-197.
101 Vogt DS, et al. Barriers to Veterans Health Administration Care in a Nationally Representative Sample of Women Veterans. Journal of General Internal Medicine. 2006;21:S19-S25. [pmid: 16637940].
102 Washington DL, et al. To Use or Not to Use: What Influences Why Women Veterans Choose VA Health Care. Journal of General Internal Medicine. 2006;21:S11-S18. [pmid: 16637939].
103 Shen Y, et al. The impact of private insurance coverage on veterans’ use of VA care: insurance and selection effects. Health Serv Res. 2008;43(1 Pt 1):267-86. [pmid: 18211529].
104 Ross JS, et al. Dual use of Veterans Affairs services and use of recommended ambulatory care. Med Care. 2008;46(3):309-16. [pmid: 18388846].
105 Zeber JE, et al. Effect of a medication copayment increase in veterans with schizophrenia. Am J Manag Care. 2007;13(6 Pt 2):335-46. [pmid: 17567234].
106 Wakefield BJ, et al. Veterans’ use of Department of Veterans Affairs care and perceptions of outsourcing inpatient care. Mil Med. 2007;172(6):565-71. [pmid: 17615833].
107 Nelson KM, Starkebaum GA, Reiber GE. Veterans using and uninsured veterans not using Veterans Affairs (VA) health care. Public Health Rep. 2007;122(1):93-100. [pmid: 17236614].
108 Mooney SE, Weeks WB. Where do women veterans get their inpatient care?. Womens Health Issues. 2007;17(6):367-73. [pmid: 18042486].
109 Hynes DM, et al. Veterans’ access to and use of Medicare and Veterans Affairs health care. Med Care. 2007;45(3):214-23. [pmid: 17304078].
110 Shen Y, et al. VA-Medicare dual beneficiaries’ enrollment in Medicare HMOs: access to VA, availability of HMOs, and favorable selection. Med Care Res Rev. 2005;62(4):479-95. [pmid: 16049135].
111 Frayne SM, et al. Gender and Use of Care: Planning for Tomorrow’s Veterans Health Administration. Journal of Women’s Health. 2006;16(8):1188-1199.
112 Frayne SM, et al. Gender Disparities in Veterans Health Administration Care: Importance of Accounting for Veteran Status. Medical Care. 2008;46(5):549-553. [pmid: 18438204].
113 LaVela S, et al. Disease Prevalence and Use of Preventive Services: Comparison of Female Veterans in General and Those with Spinal Cord Injuries and Disorders. MS. Journal of Women’s Health. 2006.
114 Singh JA, Murdoch M. Effect of Health Related Quality of Life on Women and Men’s Veterans Affairs (VA) Health Care Utilization and Mortality. Journal of General Internal Medicine. 2007;22(9):1260-1267. [pmid: 17610020].
115 Kaur S, et al. Gender differences in health care utilization among veterans with chronic pain. J Gen Intern Med. 2007;22(2):228-33. [pmid: 17356991].
116 Hatmaker AR, et al. Cost-effective use of breast biopsy techniques in a Veterans health care system. Am J Surg. 2006;192(5):e37-41. [pmid: 17071179].
117 Borrero S, et al. Brief report: Gender and total knee/hip arthroplasty utilization rate in the VA system. J Gen Intern Med. 2006;21(Suppl 3):S54-7. [pmid: 16637947].
118 Sherman SE, et al. Gender differences in smoking cessation services received among veterans. Womens Health Issues. 2005;15(3):126-33. [pmid: 15894198].
119 Lairson DR, Chan W, Newmark GR. Determinants of the demand for breast cancer screening among women veterans in the United States. Soc Sci Med. 2005;61(7):1608-17. [pmid: 16005790].
120 Chen JH, et al. Receipt of disability through an outreach program for homeless veterans. Mil Med. 2007;172(5):461-5. [pmid: 17521090].
121 Haskell SG, et al. The prevalence and age-related characteristics of pain in a sample of women veterans receiving primary care. J Womens Health (Larchmt). 2006;15(7):862-9. [pmid: 16999642].
122 LaVela SL, et al. Geographical proximity and health care utilization in veterans with SCI&D in the USA. Soc Sci Med. 2004;59(11):2387-99. [pmid: 15450711].
123 Kimerling R, et al. Evaluation of Universal Screening for Military-Related Sexual Trauma. Psychiatric Services. 2008;59:635-640. [pmid: 18511583].
124 Polusny MA, et al. The Role of Cumulative Sexual Trauma and Difficulties Identifying Feelings in Understanding Female Veterans’ Physical Health Outcomes. Gen Hosp Psychiatry. 2008;30(2):162-70. [pmid: 18291298].
125 Kelly MM, et al. Effects of Military Trauma Exposure on Women Veterans’ Use and Perceptions of Veteran Health Administration Care. Journal of General Internal Medicine. 2008;23(6):741-747. [pmid: 18414956].
126 Zinzow HM, et al. Sexual assault, mental health, and service use among male and female veterans seen in Veterans Affairs primary care clinics: a multi-site study. Psychiatry Res. 2008;159(1–2):226-36. [pmid: 18423615].
127 Sadler AG, Booth BM, Doebbeling BN. Gang and multiple rapes during military service: health consequences and health care. J Am Med Womens Assoc. 2005;60(1):33-41. [pmid: 16845766].
128 Stein MB, et al. Relationship of sexual assault history to somatic symptoms and health anxiety in women. Gen Hosp Psychiatry. 2004;26(3):178-83. [pmid: 15121345].
129 Dobie DJ, et al. PTSD Screening Status is Associated with Increased VA Medical and Surgical Utilization in Women. Journal of General Internal Medicine. 2006;21:S58-64. [pmid: 16637948].
130 Grubaugh A, et al. Female Veterans Seeking Medical Care at Veterans Affairs Primary Care Clinics: Psychiatric and Medical Illness Burden and Service Use. Women & Health. 2006;43(3):41-62. [pmid: 17194677].
131 Frueh BC, et al. Age differences in posttraumatic stress disorder, psychiatric disorders, and healthcare service use among veterans in Veterans Affairs primary care clinics. Am J Geriatr Psychiatry. 2007;15(8):660-72. [pmid: 17670996].
132 Miller EA, Rosenheck RA. Risk of nursing home admission in association with mental illness nationally in the Department of Veterans Affairs. Med Care. 2006;44(4):343-51. [pmid: 16565635].
133 Lang AJ, et al. Relationships among childhood maltreatment, PTSD, and health in female veterans in primary care. Child Abuse Negl. 2006;30(11):1281-92. [pmid: 17116330].
134 Kaplowitz RA, et al. Health care utilization and receipt of cholesterol testing by veterans with and those without mental illness. Gen Hosp Psychiatry. 2006;28(2):137-44. [pmid: 16516064].
135 Fontana A, Rosenheck R. Treatment of female veterans with posttraumatic stress disorder: the role of comfort in a predominantly male environment. Psychiatr Q. 2006;77(1):55-67. [pmid: 16397755].
136 Sherman MD, et al. Mental health needs of cohabiting partners of Vietnam veterans with combat-related PTSD. Psychiatr Serv. 2005;56(9):1150-2. [pmid: 16148334].
137 Greenberg GA, Fontana A, Rosenheck RA. Continuity and intensity of care among women receiving outpatient care for PTSD. Psychiatr Q. 2004;75(2):165-81. [pmid: 15168838].
138 Mojtabai R, et al. Use of VA aftercare following military discharge among patients with serious mental disorders. Psychiatric Services. 2003;54(3):383-388. [pmid: 12610248].
139 Maguen S, et al. Predictors of mental and physical health service utilization among Vietnam veterans. Psychological Services. 2007;4(3):168-180.
140 Rowan AB, Campise RL. A multisite study of Air Force outpatient behavioral health treatment-seeking patterns and career impact. Mil Med. 2006;171(11):1123-7. [pmid: 17153554].
141 Carney CP, et al. Women in the Gulf War: combat experience, exposures, and subsequent health care use. Mil Med. 2003;168(8):654-61. [pmid: 12943043].
142 Halek K, Murdoch M, Fortier L. Spontaneous Reports of Emotional Upset and Health Care Utilization Among Veterans With Posttraumatic Stress Disorder After Receiving a Potentially Upsetting Survey. American Journal of Orthopsychiatry. 2005;75(1):142-151. [pmid: 15709857].
143 Vogt DS, et al. Deployment Stressors and Posttraumatic Stress Symptomatology: Comparing Active Duty and National Guard/Reserve Personnel from Gulf War I. Journal of Traumatic Stress. 2008;21(1):66-74. [pmid: 18302185].
144 Westrup DA, Weitlauf JC, Keller J. I Got My Life Back! Making a Case for Self Defense Training for Older Women with PTSD. Clinical Gerontologist. 2005;28(3):113-118.
145 Vogt DS, et al. Longitudinal Investigation of Reciprocal Relationship Between Stress Reactions and Hardiness. Personality and Social Psychology Bulletin. 2008;34(1):61-73. [pmid: 18162656].
146 Mancino MJ, et al. Quality-adjusted health status in veterans with posttraumatic stress disorder. J Nerv Ment Dis. 2006;194(11):877-9. [pmid: 17102715].
147 Ouimette P, et al. Posttraumatic stress disorder and health status among female and male medical patients. J Trauma Stress. 2004;17(1):1-9. [pmid: 15027787].
148 Escalona R, et al. PTSD and somatization in women treated at a VA primary care clinic. Psychosomatics. 2004;45(4):291-6. [pmid: 15232042].
149 Asmundson GJ, Wright KD, Stein MB. Pain and PTSD symptoms in female veterans. Eur J Pain. 2004;8(4):345-50. [pmid: 15207515].
150 Lang AJ, et al. Direct and indirect links between childhood maltreatment, posttraumatic stress disorder, and women’s health. Behavioral Medicine. 2008;33(4):125-135. [pmid: 18316270].
151 Monnier J, et al. US female veterans in VA primary care: post traumatic stress disorder symptoms and functional status. Primary Care Psychiatry. 2004;9(4):145-150.
152 Becker M. The impact of childhood adversity factors on posttraumatic stress and other functioning in adult women veterans. Dissertation Abstracts International Section A: Humanities and Social Sciences. 2006;66(8-A):2830.
153 Brailey K, et al. PTSD symptoms, life events, and unit cohesion in U.S. soldiers: baseline findings from the neurocognition deployment health study. J Trauma Stress. 2007;20(4):495-503. [pmid: 17721953].
154 Schnurr PS, Lunney CA. Exploration of how gender differences in quality of life relates to posttraumatic stress disorder in male and female veterans. Journal of Rehabilitation Research and Development. 2008;45(3):383-394. [pmid: 18629747].
155 Gold JI, et al. PTSD Symptom Severity and Family Adjustment Among Female Vietnam Veterans. Military Psychology. 2007;19:72-81.
156 Berz JB, et al. Associations Between PTSD Symptoms and Parenting Satisfaction in a Female Veteran Sample. Journal of Psychological Trauma. 2008;7(1):37-45.
157 Murdoch M, et al. Mitigating Effect of Department of Veterans Affairs Disability Benefits for Post-Traumatic Stress Disorder on Low Income. Military Medicine. 2005;170(2):137-140. [pmid: 15782835].
158 Murdoch M, et al. Gender Differences in Service Connection for PTSD. Medical Care. 2003;41(8):950-961. [pmid: 12886174].
159 Murdoch M, et al. Regional variation and other correlates of Department of Veterans Affairs Disability Awards for patients with posttraumatic stress disorder. Med Care. 2005;43(2):112-21. [pmid: 15655424].
160 Dobie DJ, et al. Posttraumatic stress disorder in female veterans: association with self-reported health problems and functional impairment. Arch Intern Med. 2004;164(4):394-400. [pmid: 14980990].
161 Gahm GA, et al. Relative impact of adverse events and screened symptoms of post-traumatic stress disorder and depression among active duty soldiers seeking mental health care. Journal of Clinical Psychology. 2007;63(3):199-211. [pmid: 17115432].
162 Frayne SM, et al. The burden of medical illness in women with depression and PTSD. Archives of Internal Medicine. 2004;164(12):1306-1312. [pmid: 15226164].
163 Shipherd JC, Stafford J, Tanner LR. Predicting alcohol and drug abuse in Persian Gulf War veterans: What role do PTSD symptoms play?. Addictive Behaviors. 2005;30:595-599. [pmid: 15718078].
164 Campbell R, et al. The co-occurrence of childhood sexual abuse, adult sexual assault, intimate partner violence, and sexual harassment: A mediational model of posttraumatic stress disorder and physical health outcomes. Journal of Consulting and Clinical Psychology. 2008;76(2):194-207. [pmid: 18377117].
165 Yaeger D, et al. DSM-IV diagnosed posttraumatic stress disorder in women veterans with and without military sexual trauma. Journal of General Internal Medicine. 2006;21:S65-S69. [pmid: 16637949].
166 Himmelfarb N, Yaeger D, Mintz J. Posttraumatic stress disorder in female veterans with military and civilian sexual trauma. Journal of Traumatic Stress. 2006;19(6):837-846. [pmid: 17195980].
167 Stecker T, et al. Characteristics of women seeking intensive outpatient substance use treatment in the VA. J Womens Health (Larchmt). 2007;16(10):1478-84. [pmid: 18062763].
168 Benda B. A Study of Substance Abuse, Traumata, and Social Support Systems Among Homeless Veterans. Journal of Human Behavior in the Social Environment. 2005;12(1):59-82.
169 Gutierrez CA, et al. Predictors of aversive alcohol consequences in a military sample. Mil Med. 2006;171(9):870-4. [pmid: 17036609].
170 Lande RG, et al. Gender differences and alcohol use in the US Army. J Am Osteopath Assoc. 2007;107(9):401-7. [pmid: 17908832].
171 Dove MB, Joseph HJ. Sociodemographic profile of women entering a military substance use disorder treatment center. Mil Med. 2007;172(3):283-7. [pmid: 17436773].
172 Teh CF, et al. Gender differences in health-related quality of life for veterans with serious mental illness. Psychiatr Serv. 2008;59(6):663-9. [pmid: 18511587].
173 Wallace AE, et al. Rural and urban disparities in health-related quality of life among veterans with psychiatric disorders. Psychiatr Serv. 2006;57(6):851-6. [pmid: 16754763].
174 Forman-Hoffman VL, et al. Mental health comorbidity patterns and impact on quality of life among veterans serving during the first Gulf War. Quality of Life Research. 2005;14(10):2303-2314. [pmid: 16328909].
175 Riddle JR, et al. Millennium Cohort: the 2001–2003 baseline prevalence of mental disorders in the U.S. military. J Clin Epidemiol. 2007;60(2):192-201. [pmid: 17208126].
176 Gahm GA, Lucenko BA. Screening soldiers in outpatient care for mental health concerns. Mil Med. 2008;173(1):17-24. [pmid: 18251327].
177 Vinokur A, Pierce P, Buck C. Work-family conflicts of women in the Air Force: their influence on mental health and functioning. J Organizational Behav. 1999;20:865-878.
178 Pierce P, Vinokur A, Buck C. Effects of war-induced maternal separation on children’s adjustment during the Gulf War and two years later. J Appl Soc Psychol. 1998;14:1287-1312.
179 Frayne SM, et al. Health status among 28,000 women veterans: The VA Women’s Health Program Evaluation Project. Journal of General Internal Medicine. 2006;21(S3):S40-46. [pmid: 16637944].
180 Kimerling R, et al. The Veterans Health Administration and Military Sexual Trauma. American Journal of Public Health. 2007;97:2160-2166. [pmid: 17971558].
181 Murdoch M, et al. Functioning and Psychiatric Symptoms among Military Men and Women Exposed to Sexual Stressors. Military Medicine. 2007;172(7):718-725. [pmid: 17691684].
182 Lee TT, et al. Impact of clinician gender on examination anxiety among female veterans with sexual trauma: a pilot study. J Womens Health (Larchmt). 2007;16(9):1291-9. [pmid: 18001185].
183 Suris A, et al. Sexual assault in women veterans: an examination of PTSD risk, health care utilization, and cost of care. Psychosom Med. 2004;66(5):749-56. [pmid: 15385701].
184 David WS, et al. Making a case for personal safety: perceptions of vulnerability and desire for self-defense training among female veterans. J Interpers Violence. 2004;19(9):991-1001. [pmid: 15296613].
185 Murdoch M, et al. The Association between In-service Sexual Harassment and Post-traumatic Stress Disorder among Department of Veterans Affairs Disability Applicants. Military Medicine. 2006;171(2):166-73. [pmid: 16578990].
186 Schultz JR, et al. Child Sexual Abuse and Adulthood Sexual Assault among Military Veteran and Civilian Women. Military Medicine. 2006;171(8):723-728. [pmid: 16933812].
187 Wolfe J, et al. Gender and Trauma as Predictors of Military Attrition: A Study of Marine Corps Recruits. Military Medicine. 2005;170(12):1037-1043. [pmid: 16491944].
188 Murdoch M, et al. Prevalence of In-Service and Post-Service Sexual Assault among Combat and Noncombat Veterans Applying for Department of Veterans Affairs Posttraumatic Stress Disorder Disability Benefits. Military Medicine. 2004;169(5):392-395. [pmid: 15186007].
189 Suris A, et al. Mental health, quality of life, and health functioning in women veterans: differential outcomes associated with military and civilian sexual assault. J Interpers Violence. 2007;22(2):179-97. [pmid: 17202575].
190 Sadler AG, et al. Life span and repeated violence against women during military service: effects on health status and outpatient utilization. J Womens Health (Larchmt). 2004;13(7):799-811. [pmid: 15385074].
191 Merrill LL, et al. Premilitary intimate partner violence and attrition from the U.S. Navy. Mil Med. 2006;171(12):1206-10. [pmid: 17256684].
192 Gielen AC, et al. Domestic violence in the military: women’s policy preferences and beliefs concerning routine screening and mandatory reporting. Mil Med. 2006;171(8):729-35. [pmid: 16933813].
193 Sadler AG, et al. The military environment: risk factors for women’s non-fatal assaults. J Occup Environ Med. 2001;43(4):325-34. [pmid: 11322093].
194 Sadler AG, et al. Health-related consequences of physical and sexual violence: women in the military. Obstet Gynecol. 2000;96(3):473-80. [pmid: 10960645].
195 Kilbourne AM, et al. Oral health in Veterans Affairs patients diagnosed with serious mental illness. J Public Health Dent. 2007;67(1):42-8. [pmid: 17436978].
196 Sajatovic M, et al. Self-reported medication treatment adherence among veterans with bipolar disorder. Psychiatr Serv. 2006;57(1):56-62. [pmid: 16399963].
197 Desai MM, Rosenheck RA, Craig TJ. Case-finding for depression among medical outpatients in the veterans health administration. Medical Care. 2006;44(2):175-181. [pmid: 16434917].
198 Copeland LA, et al. Treatment adherence and illness insight in veterans with bipolar disorder. Journal of Nervous and Mental Disease. 2008;196(1):16-21. [pmid: 18195637].
199 Zivin K, et al. Suicide mortality among individuals receiving treatment for depression in the Veterans Affairs health system: associations with patient and treatment setting characteristics. Am J Public Health. 2007;97(12):2193-8. [pmid: 17971541].
200 Yano EM, et al. Toward a VA women’s health research agenda: Setting evidence-based priorities to improve the health and health care of women veterans. J Gen Intern Med. 2006;21(S3):S93-S101. [pmid: 16637953].
201 Yano EM, et al. Integration of women veterans into VA quality improvement research efforts: what researchers need to know. J Gen Intern Med. 2010;25(Suppl 1):56-61. [pmid: 20077153].
202 McQueen L, Mittman BS, Demakis JG. Overview of the Veterans Health Administration (VHA) Quality Enhancement Research Initiative (QUERI). J Am Med Inform Assoc. 2004;11(5):339-43. [pmid: 15187071].
203 Rubenstein LV, et al. From understanding health care provider behavior to improving health care: the QUERI framework for quality improvement. Quality Enhancement Research Initiative. Med Care. 2000;38(6 Suppl 1):I129-41. [pmid: 10843277].
204 Yano EM. The role of organizational research in implementing evidence-based practice: QUERI Series. Implement Sci. 2008;3:29. [pmid: 18510749].