# METHODS

## TOPIC DEVELOPMENT

This project was nominated by Linda Lipson, HSR&D Equity Portfolio Manager, and the Office of Women’s Health.

Because of the broad survey nature of this synthesis, no key questions were developed.

## SEARCH STRATEGY

We searched MEDLINE/PubMed, PsycINFO, WorldCat and Web of Science for potentially relevant articles related to women veteran and military health published between January 2004 and September 2008. For each database search, we used the medical subject heading (MeSH) terms women and veterans to search for relevant literature. We supplemented this search by contacting other sources with expertise in the area of women veteran and military health. The Department of Defense Health Affairs Division provided access to bibliographical reports on general deployment and mental health issues in Operation Enduring Freedom and Operation Iraqi Freedom (OEF/OIF) military personnel from 2002 through 2007^3^. We received additional articles from a direct request to experts in the field via a VA research list service and personal contact with approximately 15 VA women’s health researchers. We also identified additional articles by reviewing bibliographies from articles identified through our search. The search strategy is listed in Appendix 4.

## STUDY SELECTION

All titles identified through our search were screened for relevance by the members of the team. Each article deemed potentially relevant was reviewed by two physician reviewers with backgrounds in women’s health working independently (BB, FB, CH) using a standardized, one page screening form (Appendix 1) and these assessments were compared and reconciled. Disagreements in ratings were resolved through consensus resolution with the help of at least one senior member of the review team. To be included, articles had to meet criteria (a), plus at least one of criteria (b), (c), or (d). The criteria were: (a) study relates to U.S. veterans or military personnel; (b) study includes women veterans, compares men and women, or analyzes women separately; (c) study involves active duty military and involves a health condition or functional status that requires medical intervention; and (d) topic is relevant to VA healthcare or to how VA care is delivered to women (Appendix 3). An article was excluded if it was defined as a non-systematic review, editorial, commentary, or an unclear publication type.

## DATA ABSTRACTION

After the initial screening process, articles meeting inclusion criteria were further evaluated and abstracted using a structured abstract form (Appendix 2). The following data were abstracted: year(s) of study or sampling timeframe; purpose of study, outcomes reported; study population description; whether the article was women-focused or had women as a subset population, or neither; brief summary of methods; and main findings. Additional data collected covered basic information about each article: study design, sample size (both female and male), study setting (from where the study population was drawn), military period of service studied (if specified), women’s health research topic area, specific condition(s) studied and study funding.

## QUALITY ASSESSMENT

For the few clinical trials identified, we used Jadad criteria for quality assessment4. For the descriptive studies, which are by far the largest number of studies, no simple standardized assessment of quality exists, and therefore, a quality assessment protocol is not included in this review.

## DATA SYNTHESIS

We identified 5 key focus areas for the Women’s Health Evidence Synthesis Project, using high priority areas identified by the 2004 review by Goldzweig and associates1, and the VA Health Services Research and Development Service (HSR&D) funding priorities. The areas were the following:

- Deployment and post-deployment health
- Organizational research
- Quality of care
- Access to care and utilization
- Psychiatric conditions.

Below we briefly describe the relationship between these categories and those in the baseline review. We then summarize the findings of articles in each of area and highlight their significance.

## CROSS WALK BETWEEN BASELINE REVIEW AND UPDATED REVIEW

The baseline review grouped the available literature into four categories; the update review groups literature into 5 categories, reflecting the growth in the scientific literature in the areas of access, utilization, and quality of care. Figure 1 shows the cross walk between the categories for each review and provides explanatory notes.

Figure 1 Category Cross Walk

## PEER REVIEW

A draft version of this report was sent to seven peer reviewers, of which five responded. Their comments and our responses are presented in Appendix 10.