# Appendices

APPENDIX 1 SCREENER FORM

APPENDIX 2 STRUCTURED ABSTRACT FORM

APPENDIX 3 SCREENER APPLICATION GUIDELINES

APPENDIX 4 SEARCH STRATEGY

APPENDIX 5 DEPLOYMENT AND POST-DEPLOYMENT HEALTH EVIDENCE TABLE

APPENDIX 6 ORGANIZATIONAL RESEARCH EVIDENCE TABLE

APPENDIX 7 QUALITY OF CARE EVIDENCE TABLE

APPENDIX 8 ACCESS AND UTILIZATION EVIDENCE TABLE

APPENDIX 9 PSYCHIATRIC/MENTAL HEALTH ISSUES EVIDENCE TABLE

APPENDIX 10 PEER REVIEW COMMENTS