# QUALITY OF CARE EVIDENCE TABLE

Author | Sample Characteristics | Sample Size | Design/Objective | Main Measures | Main Findings
2007^90^ | Females younger than age 50 who served in the active component of the US Armed Forces anytime between Jan 2005 and June 2006 | Females 117110 | Observational; To document prescriptions for hormonal contraceptives available through military medical facilities | Percentage of the surveillance population younger than age 50 who filled one or more prescriptions for hormonal contraceptives during a 27-month period | Hormonal contraceptive prescriptions were filled for more than half (54.2%) of all females who served in the active US military. The majority of females who were prescribed hormonal contraceptives were <25 years old (51.2%), white (55%), and not married (56.7%). Females in their twenties were more likely than those younger or older to receive prescriptions for hormonal contraceptives – overall and for each type except the IUD with progestin.
Albright 2005^84^ | Active duty female soldiers presenting at an Army Medical Center or clinic with dysuria or vaginal symptoms | Females 238 | Observational; To identify whether specific behavior patterns (e.g., fluid restriction, use of mechanical devices, and postponement of voiding) were associated with dysuria. | Voiding frequency during day or night and behaviors associated with dysuria | Voiding frequency was lower during day or night in the field for women with dysuria. More women in dysuria group reported fluid restriction; were treated for dysuria in the field or after field duty; and used tampons, pads or devices to control urinary incontinence during field duty. More women with dysuria postponed voiding during field or regular duty.
Araneta 2004^41^ | Military women who were admitted to military hospitals for pregnancy-related diagnoses between August 2, 1990 and May 31, 1992 | Females 1110 | Observational; (1) To enumerate Gulf-War (GW) exposed conceptions (2) characterize reproductive outcomes among GW-exposed conceptions and (3) to compare reproductive outcomes of GW-exposed pregnancies with postwar conceptions of women GW veterans and women nondeployed veterans who belonged to deployed units. | The number of pregnancies, number of postwar conceptions (both deployed and nondeployed), similarity of adverse reproductive outcomes, number of spontaneous abortions and ectopic pregnancies | Gulf War-exposed conceptions and nondeployed conceptions had similar outcomes. However, GW veteran postwar conceptions were at increased risk for ectopic pregnancies and spontaneous abortions.
Barnard 2003^82^ | National sample of female veterans who had at least 1 visit between July 1, 1994 and June 30, 1995, and were still menstruating | Females 1736 | Observational; To assess the prevalence of menstrual symptoms and the degree to which these symptoms affect health status, by comparing women with and without menstrual symptoms. | All eight domains of short form (SF-36) health status survey | Of the 1744 menstruating women, 67% answered yes to at least one of the 3 items relating to menstrual symptoms. Women with menstrual symptoms had significantly lower scores for all domains of the SF-36 (p<.01), except energy and vitality (p<.05), both before and after adjustment for sociodemographic, psychosocial, and comorbidity variables. Results remained unchanged when the analyses were repeated and limited only to women without a depression or a sexual trauma history.
Barnett 2006^75^ | Male and female veterans and nonveterans in VA and Medicare HMOs | VA Females 3311 VA Males 120,322 Non-VA Females 88,970 Non-VA Males 68,547 | Observational; To determine if rates of inappropriate medication use in the elderly differ between the VA health care system and the private sector Medicare health maintenance organization (HMO) patients. | Rate of inappropriate prescribing in the elderly VA and Medicare patients | 1) Compared with private sector patients, VA patients were less likely to receive any inappropriate medication overall (21% vs. 29%, p<0.001), and in each classification: always avoid (2% vs. 5% p<0.001), rarely appropriate (8% vs. 13%, p<0.001), and some indications (15% vs. 17%, p<0.001). 2) The rate of inappropriate drug use was lower in the VA compared with the private sector for males (21% vs. 24% p<0.001) and females (28%vs. 32%, p<0.001).
Bean- Mayberry 2006^50^ | Random sample of female veterans using VA primary care or women’s clinics across 5 states | Females 1447 | Observational; To explore effect of race on primary care quality and satisfaction among women in the VA | 4 domains of primary care delivery: patient preference for provider; interpersonal communication; accumulated knowledge; and coordination of care | -Race had no association with any of the 4 primary care domains or with overall satisfaction. Gynecological care from VA provider was associated with perfect ratings on patient preference for provider (OR 2.0, 95% CI 1.3, 3.1) and satisfaction (OR 1.6, 95% CI 1.2, 2.3), while female provider was associated with interpersonal communication (OR 1.9, 95% CI 1.4, 2.6).
Bean- Mayberry 2006^54^ | Female veterans in women’s clinics or primary care clinics at 10 VA medical centers in one region | Females 1080 | Observational; To determine whether separate or combined effects of provider gender, availability of gynecologic services from the provider, and women’s clinic setting improve patient ratings of primary care. | Patient perceptions of primary care were measured using the validated 19-item Components of Primary Care Index (CPCI) which consists of 4 multi-item primary care domains: patient preference for regular provider; interpersonal communication with provider; coordination of care; and accumulated knowledge. | -Female provider was significantly associated with perfect ratings for communication and coordination. -Providing gynecologic care was significantly associated with perfect ratings for male and female providers. Patients who used a women’s clinic and had a female provider who gave gynecologic care had perfect or nearly perfect ratings for preference for provider, communication, and accumulated knowledge. Gynecologic services are linked to patient ratings of primary care separate from and in synergy with the effect of female provider.
Bean- Mayberry 2003^52^ | Female veterans from 8 VA medical centers in 3 states | Females 971 | Observational; To compare patient satisfaction in women’s clinics (WCs) versus traditional primary care clinics (TCs) | Overall satisfaction and gender-specific satisfaction as measured by the Primary Care Satisfaction Survey for Women (PCSSW) | -Women enrolled in women’s clinics were more likely than those in traditional primary care clinics to report excellent overall satisfaction (odds ratio, 1.42; 95% CI, 1.00 to 2.02; p = 0.05). Multivariate models demonstrated that receipt of care in women’s clinics was a significant positive predictor for all 5 satisfaction domains (i.e., getting care, privacy and comfort, communication, complete care, and follow-up care) with the gender-specific satisfaction instrument (PCSSW).
Bierman 2007^73^ | Male and female veteran VA users with VA pharmacy use | Females 19,115 Males 946,641 | Observational; To assess sex differences in rates of inappropriate prescribing before and after accounting for potentially appropriate indications and to examine sex differences in predictors of inappropriate drug use. | Rate of inappropriate prescribing in the elderly by gender using Beers criteria | 1)Women were more likely to have received potentially inappropriate medications in all 3 categories: always avoid, rarely appropriate and some indications, even after accounting for diagnosis (always avoid: OR 1.73, 95%CI 1.55–1.94; rarely appropriate: OR 1.18, 95%CI 1.12–1.24; some indications: OR 1.18, 95%CI: 1.14–1.23). 2)In stratified analyses (women only), receiving geriatric care was protective of inappropriate prescribing (OR 0.64, 95%CI 0.53–0.78). 3)Older women in a VA hospital setting are at greater risk for receiving inappropriate drugs than older men.
Busch 2004^77^ | Female and male veteran VA users and non-VA population of employees and retirees with depression diagnosis and initiation of antidepressants. | VA Females 3028 VA Males 24,685 Non-VA Females 3295 Non-VA Males 1557 | Observational; To compare quality of pharmacotherapy for patients with major depression in the VA and the private sector. | Quality of depression care pharmacotherapy (HEDIS measure of antidepressant medication management, e.g., proportion of patients with 3 or more follow-up office visits in 12 weeks after depression diagnosis) | 1)More than 80% of patients who began antidepressant treatment achieved guideline-level acute-phase treatment. 2)Few differences in the quality of pharmacotherapy for depression were found between VA and the private sector, with VA slightly outperforming in prescription of antidepressants during acute (84.7% vs. 81.0%) and maintenance phases of treatment (53.9% vs. 50.9%). 3)Patient characteristics associated with pharmacotherapy quality included being female, and having a comorbid diagnosis of substance use, bipolar disorder, or anxiety or adjustment disorder.
Chireau 2006^91^ | Convenience sample of female veterans who applied for VA maternity benefitsbetween 1999 and 2005 | Females 33 | Observational; To examine demographic and clinical characteristics of female veterans at the Durham VAMC who were using the VA’s fee basis mechanism, their pregnancy outcomes and the costs associated with their pregnancy care | Pregnancy events and outcomes, current medical and psychiatric conditions, and costs | Of the thirty-three veterans with complete records, 61% were white, 39% were black, and mean age was 28.5 years. Ten (32%) had at least one chronic medical condition, and 13 (39%) had at least one psychiatric condition. Adverse pregnancy outcomes occurred in 12 (36%) of the veterans, and most commonly was premature births.
Cypel 2008^80^ | National sample of female veterans with active duty orders in Vietnam or other areas between 1967 – 1972 | Females 9911 | Observational; To compare mortality patterns between Vietnam and non-Vietnam veteran cohorts to the US population | All cause mortality, all cancer mortality, cause specific mortality, crude and adjusted mortality rates, and veteran nurse mortality rates | -Women Vietnam veterans showed a significant deficit (ARR 0.78, 95% CI 0.62, 0.98) in circulatory system disease relative to non-Vietnam veterans, but significant deficits were also observed when both cohorts were compared with women in the U.S. population (SMR 0.65, 95% CI 0.54, 0.77, SMI 0.82, 95% CI 0.73, 0.93, respectively). -Vietnam veterans were at significantly greater risk of mortality from motor vehicle accidents than non-Vietnam veterans (ARE 2.60, 95% CI 1.22, 5.55) and this appeared to be specific to service in Vietnam based upon comparisons to the U.S. population.
del Junco 2008^85^ | Random sample of female patients age 52 years and older from the National Registry of Women Veterans | Females 14093 | Observational; To assess internal and external validity in a nationwide, population based trial of an intervention to promote regular mammographic screening | Mammography rates from self report and VHA records for each group of patients | Despite the time lags for baseline survey mailings, respondents in the 5 study groups were similar in race/ethnicity, ever use of VA health care, and age group. Groups 4 and 5 were least likely to respond to the baseline survey or phone calls. At study’s end, no between group differences in participant’s follow up survey response mode or other characteristics were present. At the year 2 follow up survey, 61% of group 3 reported at least two mammograms since the baseline survey mailing compared to 59% of group 5 (p=.388) in the two years prior to their baseline survey. Overall mammographic coverage was lower in group 5 compared to groups 1–4 combined (82.3% vs. 85.1%, p=.024).
Desai 2005^58^ | Female and male VA patient respondents to the National VA Customer Feedback Survey, identified as having a visit to a VA general medicine, primary care, or women’s clinic between March 1 – April, 23, 1999, who were not admitted to the hospital in the same time period | Females 5170 Males 45362 | Observational; The objective of this study was to assess the role of psychiatric illness in satisfaction with outpatient primary care services in the VA. | core satisfaction with healthcare, including overall coordination of care among providers; open sharing of information with the patient; timeliness and accessibility of service; courtesy of staff; emotional support; coordination of care; specialist provider access; pharmacy access; and continuity of care | After controlling for patient characteristics (e.g., gender, age, disability, acute vs. routine visit) and subjective health, patients with schizophrenia, posttraumatic stress disorder, drug abuse, depression, and other psychiatric disorders reported significantly lower satisfaction with their outpatient primary care. Dissatisfaction was particularly reported for access to care and overall coordination of care.
Etzioni 2006^61^ | Female and male VA patients sampled nationally through the VA Office of Quality and Performance (OQP) in fiscal year 2002 (October 1, 2001 to September 30, 2002). | Females 5360 Males 34510 | Observational; To examine patterns of colorectal cancer screening and follow-up within the Veterans Health Administration. | Evidence of colorectal cancer screening defined as 1) fecal occult blood test (FOBT; 3 test cards must be returned) in last 12 months, 2) flexible sigmoidoscopy in last 5 years, or 3) colonoscopy in last 10 years; and receipt of follow-up testing after positive FOBT within the follow-up population. | (1) Screening was more likely in patients aged 70 to 80 years than in those younger or older. (2) Female gender, black race, lower income, infrequent primary care visits, and a recent admission to a nursing home were associated with lower likelihood of screening. (3) Forty-one percent of patients were not offered any kind of total colon examination within 6 months of a positive FOBT.
Fan 2005^57^ | Female and male patients in primary care clinics at 7 VA medical centers participating in the Ambulatory Care Quality Improvement Project who returned the baseline Seattle Outpatient Satisfaction Questionnaire (SOSQ) were eligible for this study. | Females 781 Males 20908 | Observational; The objective of this trial was to determine whether providing visit-based reports about patient self-reported health status, routine clinical data, and guideline recommendations to providers would improve patient care outcomes | Patient satisfaction with communication skills and humanistic qualities of primary care providers, satisfaction with delivery of health care services, continuity of care (i.e, seeing the same provider), provider characteristics, demographic factors, socioeconomic status, health status, clinic site, patient utilization of services | Increasing self-reported continuity of care was associated with higher patient satisfaction. Patients who reported always seeing the same provider had higher mean humanistic scores and satisfaction scores than those who rarely or never saw the same provider. Female patient gender was associated with improved satisfaction, and increasing age of patient is associated with improved satisfaction until approximately age 70. There was significant variability in mean satisfaction between clinic sites. Patients who received care in primary care clinics within 12 months of returning the questionnaire were more satisfied than those who did not. Among provider characteristics, female clinicians were associated with greater humanistic scores. Provider characteristics were not significantly associated with organizational scores.
Fink 2007^71^ | Veteran and non-veteran female surgical patients at VA and private sector hospitals | VA Females 5157 Non-VA Females 27,467 | Observational; To test the applicability of the National Surgical Quality Improvement Program (NSQIP) to the private sector in 128 VA hospitals and 14 private academic medical centers for female surgical patients | Unadjusted any cause 30-day mortality inside or outside the hospital, unadjusted morbidity (length of stay, return to the operating room, 19 postoperative complications during the 30-day postop period) | Unadjusted 30-day mortality was virtually identical in the two groups (1.3%). The unadjusted morbidity rate was slightly, but notably, higher in the private sector (10.9%) as compared with that observed in the VA (8.5%, p < 0.0001). The indicator variable for system of care (VA versus private sector) was not statistically significant in the mortality model, but substantially favored the VA in the morbidity model (odds ratio 0.80, 95% CI 0.71, 0.90). Risk-adjusted morbidity is higher in the private sector. The rates of urinary tract infections in the two populations may account for much of the latter difference (3.05% versus 1.75%, p < 0.0001).
Frayne 2003^79^ | National random sample of female veterans using VA ambulatory care | Females 3543 | Observational; To determine whether known cardiac risk factors are more prevalent among women veterans who report having sustained sexual assault while in the military | Self-report of current diabetes, hypertension, obesity (BMI ≥ 30), cigarette smoking, problem alcohol use (score > 3 on the TWEAK), sedentary lifestyle (moderate physical activities < 3 times per week), prior hysterectomy (for the subset with age < 40, the premature menopause threshold), and past year cholesterol testing, also current hormone replacement therapy, contact with a medical doctor (in or outside VA) within the past 3 months | -Obesity, smoking, problem alcohol use, sedentary lifestyle, and hysterectomy before age 40 were found to be more common in women reporting a history of sexual assault while in the military than in women without such a history.
Friedemann-Sanchez 2007^66^ | Random sample of veterans stratified by sex at Minneapolis VAMC | Females 27 Males 43 | Observational; To explore colorectal cancer (CRC) screening barriers, attitudes and preferences by gender. | CRC screening barriers, attitudes, beliefs, preferences, and knowledge and information needs by gender | Female and male participants reported similar preferences for CRC screening mode. Women viewed the preparation for endoscopic procedures as a major barrier to screening while men did not; women and men expressed different fears and information preferences for endoscopic procedures; and women perceive CRC as a male disease thus feeling less vulnerable to it. Pain was foremost issue in the majority of men’s minds, and vulnerability in women’s.
Haas 2007^32^ | All women presenting to the obstetrics clinic for prenatal care appointments at Naval Hospital Camp Lejeune from Jan to Apr 2005 | Females 463 | Observational; To determine if having a partner deployed in the military during wartime increased the stress levels in pregnant women and to determine predictors of reporting higher stress | Relationship between having a deployed partner and stress levels in pregnant women | Over 88.2% of patients responded to the survey. Women with deployed partners more often reported higher stress levels than those with homeland partners (39.6% and 24.2%, respectively; p<0.01). Logistic regression revealed that having a partner deployed (OR 1.89, 95% CI 1.00–3.57, p=0.04), being active duty (OR 2.64, 95% CI 1.43–4.87, p=<0.01), advanced gestational age (OR 1.04, 95% CI 1.00–1.07, p=0.03) and having >1child at home (OR 2.30, 95% CI 1.12–4.73, p=0.02) all predicted higher stress reporting. Having a support person present was protective against stress (OR 0.40, 95% CI 0.20–0.78, p=<0.01).
Harriott 2005^56^ | Female active duty, stratified random sample of beneficiaries who received maternity care (gave birth) at one of 44 military hospitals between July 1 and September 30, 2001. | Females 2124 | Observational; To examine women’s evaluations of maternity care with respect to decision-making, confidence, trust in health care providers, and treatment within the military hospital, and to identify aspects of the childbirth experience that were most important to women’s recommendations to others of military hospitals. | Patient perceptions of care across multiple dimensions: (1) respect for patient preferences; (2) coordination of care; (3) information and education; (4) attention to physical comfort; (5) emotional support; (6) involvement of family and friends; (7) continuity and transition; and (8) courtesy and availability of staff; overall hospital experience; demographic and clinical information; and assessment of treatment with respect and dignity. | Response Rate was 41%. (1) Less than 50% of respondents would recommend the military hospital to family and friends. (2) The study hospitals had more problems reported than national averages for nearly all dimensions of care. (3) Treatment consistent with individual needs for respect, dignity, and involved decision-making were the primary factors associated with significantly higher overall evaluations; women who expressed higher levels of trust in doctors, midwives, and nurses were more likely to have significantly higher overall evaluations of their care.
Haskell 2004^88^ | Female patients identified through VA pharmacy records as taking combination estrogen and progesterone hormone therapy in 1 VA system | Females 48 | Observational; To evaluate women’s responses to the publication of the Women’s Health Initiative (WHI, 2002) and to determine what proportion of women stopped hormone replacement therapy (HRT) and whether the technique of discontinuation affected recurrence of menopausal symptoms. | Cessation of HRT, including abrupt vs. tapered cessation; recurrence of menopausal symptoms. | Over three-quarters (77%) of women stopped taking HRT (20 abruptly and 17 tapered off). Of those women who stopped taking HRT abruptly, 8 (40%) experienced recurrent menopausal symptoms compared to 12 (71%) of those who tapered off of HRT. Tapering off of HRT did not reduce the recurrence of menopausal symptoms compared to abrupt cessation.
Haskell 2007^81^ | All female veterans who used VA medical facilities for medical care and also received hormone therapy (HT) through VA pharmacies in 2001 | Females 36,222 | Observational; To determine whether the decline in HT use nationally also occurred among the population of female veterans taking HT in 2001, and determine if it continued into 2004, and identify whether treatment in a specialized women’s health clinic versus other clinics affected HT discontinuation rates | HT medication use was defined as any hormone medication use within the specified calendar year, discontinuation was defined as no longer having any use in the specified year | By 2004, 23,924 (66%) had discontinued HT. Subjects who had used a VA women’s clinic or were younger (40–54 years of age) were significantly less likely to discontinue HT. Discontinuation rates in the VA system parallel those in the private sector. However, patients with any use of VA women’s clinics were less likely to discontinue HT.
Hynes 2004^72^ | Female and male breast surgery patients with procedures at VA facilities confirmed as having breast cancer using surgical pathology reports were included. | Females 358 Males 120 | Observational; To examine trends and outcomes for breast cancer surgery performed at VA hospitals. | 30-day morbidity rates (measured as occurrence of 1 or more of 21 complications, such as wound infections, within 30 days), 1-year hospital readmission rates, 30-day mortality, post-operative length of stay (LOS). | 1)1,333 breast operations were performed over the course of this 6-year interval (average 1–38/hospital), with 478 confirmed breast cancer (75% were women). Female breast cancer surgery patients were younger, less likely to be married and more likely to be low income compared to men. Female patients were also more likely to be functionally independent and less likely to have reported frequent alcohol use, to have absent peripheral pulses or to have used steroids. 2)30-day morbidity rates, 1-year hospital read-mission rates and 30-day mortality rates were very low for both men and women, post-operative LOS averaged 6.8 days. 3)Lower income, longer operation times and older age increased the likelihood of 30-day morbidity.
Jha 2005^62^ | National sample of female and male VA users | 6642–86* Females/Males not specified | Observational; | 9 quality measures: 3 preventive services (pneumococcal and influenza vaccinations and colorectal cancer screening); and 6 chronic disease measures (diabetic eye exam screening, annual glycosylated hemoglobin testing [HbA1c], aspirin after myocardial infarction [MI], beta blocker after MI, and blood pressure </= 140/90 mmHg) | Adjusting for differences in age and hospital characteristics, women and men received comparable care for both preventive care and chronic disease management overall. Age group differences did occur within the quality measures. Among those <65 years, women were more likely to receive HbA1c testing (OR 1.13, 95%CI 1.03–1.25) and adequate hypertension control (OR 1.09, 95%CI 1.00–1.18) but less likely to receive pneumococcal vaccine (OR 0.78, 95%CI 0.73–0.83). While for older patients age >65 years, women were less likely to receive adequate hypertension control (OR 0.82, 95%CI 0.75–0.90) and pneumococcal vaccination (OR 0.92, 95% CI 0.86–0.99).
Johnson 2007^69^ | Female patients undergoing vascular surgery at 14 private and 128 VA hospitals | VA Females 458 Non-VA Females 3535 | Observational; To compare risk-adjusted 30 day postoperative vascular surgery mortality and morbidity in females in VA and selected University Medical Centers | 30 day post-operative morbidity and mortality compared, patient clinical characteristics, and operative data | • -Compared with their VA counterparts, women undergoing vascular operations at private sector hospitals had a higher incidence of preoperative co-morbidities; after risk adjustment, mortality did not differ substantially. • -Despite risk adjustment, the incidence of postoperative morbidity in the VA patients was considerably lower, suggesting unidentified differences in hospital populations, their processes of care, or both.
Johnson 2006^89^ | Female veterans enrolled at the VA Puget Sound Health Care System in 1998 | Females 1219 | Observational; To determine the prevalence and frequency of mastalgia and its association with psychiatric conditions and unexplained pain syndromes | Breast pain in the past year, categorized as infrequent (1x/month) or frequent (1x/week) mastalgia; posttraumatic stress disorder (PTSD), depression, panic disorder, and alcohol misuse with validated screening tests, self-reported chronic pelvic pain, fibromyalgia, and irritable bowel syndrome | Fifty-five percent of respondents reported past-year mastalgia. Of these, 15% reported frequent mastalgia. Compared to women without mastalgia, women reporting frequent mastalgia were more likely to screen positive for PTSD (OR 5.2, 95% CI 3.2 to 8.4), major depression (OR 4.2, 2.6 to 6.9), panic disorder (OR 7.1, 3.9 to 12.8), eating disorder (OR 2.6, 1.5 to 4.7), alcohol misuse (OR 1.8, 1.1 to 2.8), or domestic violence (OR 3.1, 1.9 to 5.0), and to report fibromyalgia (OR 3.9, 2.1 to 7.4), chronic pelvic pain (OR 5.4, 2.7 to 10.5), or irritable bowel syndrome (OR 2.8, 1.6 to 4.8).
Johnson 2006^78^ | All female veteran VA users in local area of 1 VA Healthcare System | Females 1555 | Observational; To describe the association between obesity and television viewing practices among women veterans. | Presence of overweight or obesity by body mass index, television viewing practices, physical activity, screening for depression and PTSD | • -Watching television >2 hours per day and eating or snacking while watching television were each associated with obesity (OR 1.4, 95% CI 1.1, 1.8; and OR 1.3, 95% CI 1.0, 1.7, respectively), after adjusting for patient characteristics. Results were similar when PTSD was included in model instead of depression. • -Women who both watched >2 hours of television per day and ate or snacked while viewing were almost twice as likely to be obese (OR 1.9, 95% CI 1.4, 2.6).
Katzburg 2009^65^ | Female veteran smokers | Females 33 | Observational/Qualitative; To design a new smoking cessation program tailored for women veterans | Identify critical components of an ideal smoking cessation program | Women veterans identified critical components of an ideal program, emotional support and choice, suggesting the need for a personalized program. The Expert Panel designed an individualized menu-driven smoking cessation program that included five programs as well as a variety of quit/support tools. In the pilot, women completing the designed booklet selected multiple menu options, demonstrating enthusiasm for program components. The traditional VA program was the least selected program option.
Katzburg 2008^64^ | Female veteran smokers with a visit at one of the two VA Greater Los Angeles women’s clinics in the past year | Females 23 | Observational/Qualitative; To report on the results of 4 focus groups with female smokers emphasizing the components of an ideal program to identify potential new smoking cessation interventions. | Descriptive themes for an ideal smoking cessation group for women | Support and choice were the major themes culled from the descriptive analyses. Types of support included educational and emotional support from professional, peer and self-support mechanisms. Informal and formal peer-support mechanisms were supported in the form of a buddy/sponsor or traditional alcoholics anonymous program style. Choice was a theme repeated across groups in discussions of choices of support, formats for support (individual face to face, telephone, email), or the tangible components of a program.
Korthius 2004^63^ | Female and male veterans with HIV infection treated at VA facilities | Females 59 Males 4006 | Observational; To assess the level of adherence to lipid screening guide-lines among providers caring for HIV-infected veterans exposed to protease inhibitors (PI) and to identify facility-level predictors of adherence to lipid-screening guidelines. | lipid screening within first 6 months of PI use; number of months from first PI use to triglyceride/lipid test | (1)Six in 10 veterans taking PIs received recommended lipid screening. (2)In the full model, older age, Latino ethnicity, diabetes, hyperlipidemia history, and urban location are positive predictors of lipid screening, while IVDU exposure, heterosexual orientation, and unknown HIV risk were negative predictors of lipid screening by 6 months.
Lang 2005^55^ | Female veterans who utilized the VA San Diego Healthcare System in 1998 at five different sites | Females 221 | Observational; To examine the association between satisfaction with general medical services and trauma-related mental health symptoms in women. | overall satisfaction with visit; satisfaction with the provider; satisfaction with the clinic | The majority of patients were pleased with care they received. Older age and better mental health were significantly associated with greater overall satisfaction. The association between PTSD symptoms and satisfaction approached significance. Only general mental health reached significance individually with both satisfaction with the provider and the clinic. Women with more PTSD symptoms appear to be more satisfied with their overall care and with their provider.
Lautz 2007^70^ | Female and male VA and non-VA (private sector, PS) gastric bypass surgery patients from 12 VA medical centers and 12 private sector medical centers | VA Female 112; VA Male 262; Non-VA Female 1656; Non-VA Male 408 | Observational; To evaluate outcomes and predictors of morbidity in VA and non-VA (PS) patients undergoing Roux-en-Y gastric bypass (RYGB) during the Patient Safety in Surgery (PSS) Study | patient demographics (age, race), preoperative co-morbidities (smoking, alcohol use, history of co-morbid conditions, pulmonary and central nervous system function), preoperative laboratory values, and variables related to the operation (hospital type, open surgical procedure), and 30-day post surgical outcomes | • -The odds of postoperative morbidity for VA versus PS female patients was 1.14 (95% CI, 0.63–2.05), and for male patients 2.29 (95% CI, 1.28–4.10). • -The VA male subset showed higher risk-adjusted postoperative morbidity compared with the PS male subset. The VA and PS female subsets had equivalent risk-adjusted post-operative morbidity.
Maciejewski 2005^97^ | Female and male veterans (from a prior study trial) with a primary care provider and at least one primary care visit in the year prior to the study intervention | Females 217 Males 14232 | Observational; To evaluate the performance of different prospective risk adjustment models of out-patient, inpatient, and total expenditures of veterans who regularly use Veterans Affairs (VA) primary care | Total expenditures of VA care during a 1-year period from the index date based on the sum of inpatient and outpatient expenditures. | In all expenditure models, administrative-based measures performed better than self-reported measures, which performed better than age and gender. Prior outpatient expenditures predicted outpatient expenditures best by far (R^2^=42 percent). Models with multiple measures improved overall prediction, reduced over-prediction of low expenditure quintiles, and reduced under-prediction in the highest quintile of expenditures.
Maguen 2005^83^ | Transgender (male to female) veterans who consented to participate in one VA facility | Females 6 | Observational/Qualitative; To provide a case study description of a cognitive behavioral therapy (CBT) program for transgender male to female (MTF) veterans | Demographic data, qualitative illustrations | Most participants (n=4) experienced the following issues: employment problems; housing issues; lack of social support; anxiety or depression; significant trauma history; and PTSD symptoms. Women in the group showed improvement on measures of anxiety and depression from pre- to post-treatment. The group appeared to reduce transgender related isolation and stigma.
McEachrane-Gross 2006^96^ | Female and male veterans using the outpatient oncology or pain clinics at the Jamaica Plains campus of the Boston Healthcare System | Females 17 Males 245 | Observational; To measure the prevalence of selected complementary and alternative medicine (CAM) use among veterans attending oncology and chronic pain clinics, and to describe the characteristics of CAM use in this population | Use of 6 common CAM (herbs, dietary supplements, chiropractic care, massage therapy, acupuncture and homeopathy) | Seventy-two patients (27.3%) reported CAM use within the past 12 months. CAM use was associated with more education (p = 0.02), higher income (p = 0.006), non-VA insurance (p = 0.003), additional care outside the VA (p = 0.01) and the belief that lifestyle contributes to illness (p = 0.015). The diagnosis of chronic pain versus cancer was not associated with differential CAM use (p = 0.15). No difference in CAM use occurred by gender; however, women were only 7% of the sample.
McQueen 2008^98^ | National sample of women veterans aged 52 years or older who were participating in a repeat mammography intervention trial | Females 3414 | Observational; To examine predictors or three single-item measures of patient perceived susceptibility to breast cancer (absolute perceived risk, ordinal risk, and comparative risk likelihood (i.e., their own risk compared with other women) | Perceived risk, demographics, health status, health behaviors | Breast symptoms and greater cancer worry increased patient perceived susceptibility to breast cancer for all 3 dependent measures. Other predictors varied by dependent measure.
Miller 2008^92^ | | | Observational; To assess incidence of angioedema and the potential determinants. | Angioedema cases among patients on antihypertensives; angioedema rates by angiotensin converting enzyme inhibitors (ACE) or other antihypertensive agents; relative risk for angioedema by ACE or other agent | Overall, 0.20% of ACE initiators developed angioedema while on the medication and incidence rate was 1.97 cases per 1000 person years. The rate of angioedema on other agents initiated was 0.51, and the adjusted relative risk estimate was 3.56 (2.82–4.44). 55% of cases occurred within 90 days of first ACE use. Nearly 58.3% of angioedema cases were estimated to be due to starting ACE. Angioedema rates were 50% higher in women. However, no female specific incidence data were presented.
Mrus 2006^95^ | Convenience sample of veterans and nonveterans presenting at either a VA medical center or a non-VA medical center (4 sites) | Females 63 Males 387 | Observational; To compare health-related quality of life (HRQoL) between patients receiving care in Veterans Administration (VA) settings (veterans) and non-VA settings (non-veterans), and to explore determinants of HRQoL and change in HRQoL over time in subjects living with HIV/AIDS | Determinants of HRQoL which included health status, health ratings, etc (e.g., overall function, symptom bother, health ratings) | Compared with nonveterans, the veteran population was older and consisted of a higher proportion of males. On scales ranging from 0 (worst) to 100 (best), veterans reported significantly poorer overall function. Determinants associated with multiple HRQoL outcomes in multivariable analyses were: symptom bother, overall function, religiosity/spirituality, depressive symptoms, and financial worries. Only 14% of the overall sample was female and differed by veteran status. Increased number of bothersome symptoms was associated with female gender.
Pierce 1999^42^ | Stratified, random sample of US Air Force military women selected from a Department of Defense database who served in Operation Desert Shield or Desert Storm | Females 525 | Observational; To provide baseline health information on a randomized sample of military women serving during the Persian Gulf War. | Prevalence of gender specific health problems, rate of health care utilization, satisfaction with military and civilian care during respondents’ military careers | • -The most prevalent gender-specific problems were problems during pregnancy (41%), urinary tract infection (34%), headache (33%), and menstrual irregularities (32%) and abnormal Pap smear (27%). • - Of note, many women did not seek health care for their problems. • -In this overall group, 76% reported using military health care, 41% used civilian health care, and only 3% reported using the VA for care. • -Overall, for 15 of 18 conditions, satisfaction ratings were higher for civilian care.
Pugh 2006^74^ | Male and female veteran VA users with VA pharmacy use | Females 21,342 Males 1,075,019 | Observational; To use HEDIS 2006 criteria to determine the rate of potentially inappropriate prescribing in the elderly (PIPE) and to determine if patient risk factors are similar to those found using Beers criteria. | Rate of inappropriate prescribing in the elderly using HEDIS 2006 criteria | 1)Results for the HEDIS 2006 measure were similar to those of the 1997 Beers criteria. 2) Overall, 19.6% of the cohort received at least 1 drug included in the HEDIS 2006 criteria, and 3.9% received 2 or more HEDIS 2006 drugs; the oldest of the elderly were at lower risk of PIPE and the youngest of the elderly were at greater risk. 3)Rates of PIPE varied between women and men (23.3% of women and 19.2% of men received 1 or more HEDIS drugs). 4)The count of unique drugs was the strongest predictor for both men and women: the risk increased for those receiving 10 or more drugs (men adjusted OR 8.2, 95%CI 8.0–8.4; women adjusted OR 9.6, 95%CI 8.2–11.2).
Pugh 2005^76^ | Female and male veterans aged 65 and older having at least one VA outpatient visit in Fiscal Year 2000 | VA Females 25,309 VA Males 1,240,125 | Observational; To identify inappropriate prescribing using criteria for proper use developed by the Agency for Healthcare Research and Quality and dose-limitation criteria defined by Beers, and to describe duration of use and patient characteristics associated with inappropriate prescribing for older adults | Appropriate use/inappropriate use of drugs; patient characteristics and duration of use associated with inappropriate use | After adjusting for diagnoses, dose, and duration, inappropriate prescribing decreased from 33% to 23% and exposure to inappropriate drugs was prolonged. Pain relievers, benzodiazepines, antidepressants, and musculoskeletal agents constituted 61% of inappropriate prescribing. Whites, patients with psychiatric comorbidities, and patients receiving more medications were mostly likely to receive inappropriate drugs. Women were more likely to receive Zhan criteria drugs; men were more likely to receive dose-limited drugs.
Sohn 2006^87^ | All female and male VHA users 18 years or older who were veterans and used either inpatient or outpatient care in the VA in the current or previous year | | Observational; To describe the prevalence rates of urologic cancers and selected benign urologic conditions and their trends between 1999 and 2002 for those who have been using healthcare from the VA | Prevalence rates of 8 high priority urologic diseases including prostate, bladder, and kidney cancers, renal mass, interstitial cystitis, prostatitis, erectile dysfunction, and urethral stricture, and 13 overall urologic conditions (also includes peyronies disease, infertility, undescended testis, hypospadias, and testicular cancer). | Among conditions evaluated, prostate cancer was listed as a primary diagnosis for 5.4% of VHA users in 2002, followed in decreasing prevalence by erectile dysfunction (2.9%), renal mass (1.5%), interstitial cystitis (14%), and prostatitis (1.1%). Age-adjusted rates showed significant increases for renal mass (31%), interstitial cystitis (14%), and erectile dysfunction (8%) between 1999 and 2002. While no major findings are reported by gender, interstitial cystitis was almost twice as prevalent among female compared to male users.
Straits-Troster 2006^67^ | Female and male random sample of veterans receiving care at VA out-patient clinics during the November 2003 – March 2004 influenza season | Females 4053 Males 113561 | Observational; To assess racial/ethnic differences in influenza vaccination in VA and to examine barriers to and facilitators of influenza vaccination among veteran outpatients aged 50 years and older. | Influenza vaccination barriers and facilitators | In the multivariate model used to calculate adjusted prevalence, age accounted for most of the racial/ethnic differences, although non-Hispanic blacks were still significantly less likely to report influenza vaccination compared to non-Hispanic whites. Gender did not have an effect on vaccination in the univariate or multivariate model. Reminder by a member of the patient’s VA healthcare team was the most frequently endorsed factor for vaccination (42.4%), followed by facility poster displays (20.8%), and family or friend’s reminder to get a vaccination (12.7%).
Tseng 2006^59^ | Female and male veterans with diabetes who used VA care, were age 65+, and enrolled in Medicare | Females 3225 Males 231,922 | Observational; To examine gender differences in diabetes care process measures and intermediate outcomes among veteran clinic users | Diabetes process of care measures included: hemoglobin A1c (HbA1c); low density lipoprotein cholesterol (LDL-C); and eye exams. Intermediate outcomes included HbA1c and LDL-C values. | Overall, there were no significant gender differences in HbA1c or LDL-C testing. However, women had higher rates of these process measures than men among the non-African American minorities. Women were more likely to have completed eye exams (OR 1.11, 99% CI 1.10, 1.23) but were less likely to have LDL-C under 130mg/dL (OR 0.77, 99% CI 0.69, 0.87).
Tseng 2006^60^ | Female veteran VA users with diabetes and disability, under age 65, and alive at the end of FY 2000 | Females 2344 | Observational; To analyze predictors of diabetes care consistent with performance standards among women VA clinic users with disability enrollment status (i.e., service connection) | Process measures included ≥1 test for glycosylated hemoglobin (HbA1c), low density lipoprotein cholesterol (LDL-C), and an eye examination in FY 2000, and intermediate outcomes included HbA1c levels and LCL-C levels for VA data only. | (1) Veteran women with disability were more likely to receive recommended tests compared to veteran women without disability. (2) Women with disability were more likely to have poor LDL-C control than men with disability; women with disability were more likely to have LDL-C testing and less likely to have poor HbA1c control compared to men with disability. (3) There is a lack of demographic, socioeconomic, and health status predictors on HbA1c control and LDL-C control, except for the association between the African-American race and poor HbA1c control. (4) Among women with disability, older veteran women were more likely to be tested for HbA1c and LDL-C values.
Vander Weg 2008^68^ | Female and male active duty recruits who entered Air Force Basic Military Training during the period from October 1999 to September 2000. | Females 7826 Males 23281 | Observational; To evaluate the use of several different alternative tobacco products (bidis, cigars, kreteks, pipes, and smoke-less tobacco [ST]) in a large sample of young adults who are vulnerable to tobacco use given their age and military status. | Four general domains were assessed, including demographics, tobacco use history, potential risk factors for tobacco use, and other health risk behaviors. | Use of any type of alternative tobacco product was significantly greater among cigarette smokers compared to non-cigarette smokers. Use of alternative tobacco products was consistently higher for males than for females. The one exception was kreteks, where prevalence rates did not differ by gender.
Vernon 2008^9^ | Random sample of female veterans 52 years and older from the National Registry of Women Veterans | Females 2681 | Experimental; To evaluate strategies to increase regular mammography screening, compare rates of completion of two or more mammograms among women randomly assigned to a tailored and targeted intervention, only targeted intervention, or survey-only control group | Self-reported mammography coverage (completion of one postintervention mammogram) and compliance (completion of two postintervention mammograms) | In none of the primary analyses did the tailored and targeted intervention result in higher mammography rates than the targeted-only intervention, and there was limited support for either intervention being more effective than the baseline survey alone.
Vogt 2008^8^ | Male and female VA employees who have patient contact at 2 VA sites | Females 89 Males 69 | Randomized Educational Trial To evaluate random assignment to educational intervention versus control group. (2 group, pretest/posttest) | Evaluation of gender-role ideology, knowledge and sensitivity among VA employees | • -Older age, direct patient contact, and years of VA employment predicted higher gender awareness and suggests a meaningful role for ‘hands-on’ experience. • -Analyses revealed significantly greater improvement in sensitivity and knowledge for participants in intervention relative to control setting. • -Contrary to expectations, the program did not result in significant improvements in gender-role ideology.
von Sadovszky 2007^86^ | Female Army personnel recruited from Army posts or reserve units throughout the U.S. | Females 131 | Observational; To ascertain Army women’s specific sexual health information needs prior to developing a theoretically based, self-administered intervention to promote safer sexual practices during deployment. | Descriptive statistics for sexual risk variables, types of information received in the past and from whom, whether or not more information was desired | Participants had moderate levels of sexual risk behaviors. Forced-choice responses yielded little desire for information regarding safer sexual practices. Women identified different sexual health and safer sexual information needs based upon whether they were at a normal duty station or during deployment.
Washington 2007^51^ | VA-eligible female veterans from one city, who were VA users and non-users | Females 51 | Observational; To determine women veterans’ perspectives and decision-making about VA health care use | Information needs, access, gender appropriateness of services and gender-related aspects of care, quality of care | • -Barriers to VA use for both VA users and nonusers included lack of information about eligibility and available services. • -Nonusers often assumed the VA did not provide women’s health care. • -All groups emphasized a requirement for a health care system focused on quality and sensitivity to women’s health issues. However, users and nonusers differed in perceptions of VA quality. • -VA environment and quality concerns led many women to limit their VA use to women’s clinics.
Weeks 2006^94^ | National sample of veterans the 1999 Large Health Survey of Veteran Enrollees who used VA for care and had at least 1 of 30 physical health diagnoses | Females 23984 Males 546528 | Observational; To determine whether urban/rural disparities persist when examining disease categories of rural and urban methods. | Health related quality of life scores (HRQoL) using the SF-36 physical component score and mental component score (PCS and MCS); 30 physical disease diagnoses (ICD-9-CM) | Most diseases were significantly more prevalent in the rural veteran population. In adjusted and unadjusted analyses, PCS was significantly lower for veterans in rural settings, and MCS was lower, but differences were less pronounced. In the multivariate adjusted regression model, female gender was significantly associated with mean PCS and MCS scores (gender difference in PCS: Coefficient: 0.47, p<0.0001; gender difference in MCS: Coefficient: 2.33, p<0.0001).
Wright 2006^53^ | Female and male VA outpatients and inpatients who responded to a mailed Survey of Healthcare Experiences of Patients (SHEP) in fiscal year 2004. | Female 5244 Males 128,318 | Observational; To compare patient satisfaction of male and female users of Veterans Health Administration (VA) services. | Patient ratings of overall quality and unique dimensions of satisfaction; socio-demographic and health related patient characteristics | In adjusted analyses, overall quality and most dimensions of satisfaction were not different for females compared to males. However, continuity of care was rated higher by females in outpatient care. Additionally, for inpatient quality, men reported higher scores after adjustment for transitions (68 vs. 65, p=0.0009), physical comfort (82 vs. 80, p=0.0003), involvement of family and friends (74 vs. 71, p=0.0024), courtesy (88 vs. 86, p=0.0001), coordination (77 vs. 74, p=0.0000), and access (80 vs. 76, p=0.0000). Women were less satisfied than men in inpatient settings. Women may be more aware of being a minority in a hospital than in outpatient settings.
Yu 2006^93^ | Final nursing home stays of all patients (n=4,879) who died in VA nursing homes between October 1, 1999, and September 30, 2000 and were 65 years or older at death | Females 117 Males 4762 | Observational; To examine the final stays of elderly patients (65 and older) who died in 111 VA nursing homes in fiscal year 2000 and to evaluate the determinants of costs of final nursing home stays. | Primary outcome measure is cost; also analyzed length of stay (LOS) and intensity of care to understand how cost is associated with these study factors. | Patients with service-related conditions had higher costs, longer LOS, and similar RUG scores in all three models. Having a living spouse was not significant in the demographic-only model for cost and LOS but was strongly significant when controlling for medical conditions for other models (2 and 3). Overall, all of the independent variables appear to be affecting costs through LOS alone, with the exception of having a living spouse and stroke. Gender was not a significant factor for cost of LOS in the generalized linear regressions.