# ORGANIZATIONAL RESEARCH EVIDENCE TABLE

Author | Sample Characteristics | Sample Size | Design/Objective | Main Measures | Main Findings
Bean- Mayberry 2007^43^ | National sample of VA sites serving 4,000 or more unique patients and delivering 20,000 or more outpatient visits in fiscal year 1998 | VA sites 155 | Observational; To understand organizational influences on the development of women’s health clinics for primary care delivery in VA facilities. | Proportion of VA Medical Centers with established women’s health clinics (WHC) for primary care (PC); organizational factors associated with presence of WHCs for primary care | -133 VA Medical centers (61%) have established WHCs for Primary Care. -The majority of WHCs providing PC services were at VAMCs (103 of 160; 64%) compared to CBOCs (30 of 59; 51%). -The only factor significantly associated with established WHCs for PC was separate primary care leadership (OR 3.62, 95%CI 1.45– 9.05).
Bean- Mayberry 2007^45^ | Original Comprehensive VA Women’s Health Centers and Department of Health and Human Services (DHHS) National Centers of Excellence in Women’s Health | VA sites 8 DHHS sites 13 | Observational; To assess and contrast the features of prototypical women’s centers in VA and DHHS | Comparison of organizational structure of comprehensive women’s health centers categorized by diffusion theory – system openness, centralization, complexity, formalization, interconnectedness and organizational slack | -All DHHS and VA centers served urban areas, and nearly all had academic partnerships. DHHS centers had three times the average caseload as VA centers. -Preventive cancer screening and general reproductive services were uniformly available at all centers, although DHHS centers offered more extensive reproductive services on-site more frequently, and VA centers more often had on-site mental health care. -The DHHS and VA sites were similar in complexity (training or fellowship programs), formalization (quality monitoring activities), interconnectedness (programs for training other providers in women’s health), and organizational slack (extended/weekend hours or same gender providers).
Cope 2006^47^ | National sample of VA sites serving at least 400 or more women veterans in fiscal year 2000 | VA sites 126 | Observational; To describe the variation in provision of hormonal and intrauterine contraception among Veterans Affairs (VA) facilities. | Provision of 2 contraceptive services: 1) prescription and management of hormonal contraception; and 2) IUD placement | -97 percent of facilities offered onsite prescription and management of hormonal contraception and 60% offered IUD placement. -Three organizational factors were independently associated with onsite IUD placements: onsite gynecologist (OR 20.35, 95% CI 7.02–58.74); hospital-based in contrast to community-based practice (OR 5.49, 95% CI 1.16–26.10); and availability of a clinician providing women’s health training to other clinicians (OR 3.40 95% CI 1.19–9.76).
Hall 2007^48^ | Sample of military sexual trauma (MST) health providers at sites in one VA regional network | VA MST Providers 34 | Observational; To measure identified factors in the MST practice environment that influence delivery of care and measure levels of perceived organizational support among MST providers | Individual, facility and regional military sexual trauma practice environment (MST-PE) variable scores and levels of perceived organizational support (POS) were calculated | -All four independent variables and four of five descriptive variables were significantly correlated with POS (p<.01 for each comparison). Scheduling was significant at p<.05. -Ethical conflicts, burnout, vicarious trauma, and isolation had negative correlations with the POS while workload, organizational culture, leadership, and MST resources were positively correlated with POS. -Wide variability existed between facilities on the POS instrument, even with the small sample size.
Seelig 2008^44^ | National sample of VA sites serving 400 or more women veterans in fiscal year 2000 | VA Sites 136 | Observational; To assess the availability of basic and advanced GYN services by clinic type and staffing arrangements | Availability of GYN services by clinic type; availability of advanced GYN services by presence of OBGYN physician or GYN clinic | -Basic gynecologic services had widespread availability across nearly all sites. -Sites were more likely to have all five advanced gynecologic services when an OBGYN physician was routinely available (p<.01 for each service) and were more likely to have endometrial biopsy and IUD insertion when a GYN clinic was available (p<.01 for each service).
Washington 2006^46^ | National sample of VA sites serving 400 or more women veterans in fiscal year 2000 | VA Sites 118 | Observational; To assess the availability of women’s health care specialists for emergency gynecological problems (GYN) and for emergency mental health conditions specific to women (WMH). | Availability of women’s health care specialists for emergency gynecologic problems (GYN) and emergency mental health (MH) conditions specific to women during clinic hours and after hours. | -The majority of sites had GYN and MH specialists available for emergencies during clinic hours (64.4% and 82.7% of sites, respectively). -Availability of specialists after hours for GYN emergencies was 39.8%, for MH emergencies was 51.7%. -Two significant predictors: separate women’s health clinic was associated with availability of emergency GYN services (beta: 0.279, p=0.023), and lower local managed care penetration was associated with availability of emergency MH conditions specific to women (beta: −0.282, p=0.024).
Yano 2006^49^ | National sample of VA sites serving 400 or more women veterans with a women’s health clinic (WHCs; n=66) compared to the original 8 VA Comprehensive Women’s Health Centers (CWHCs) | VA Sites 74 | Observational; To assess the degree to which VA medical centers WHCs compare to the original CWHC model programs. | Organizational features categorized by innovative organizational domains such as centralization (budget control), complexity (scope of services), formalization (procedures), interconnectedness (WH leadership on committees), organizational slack (budget changes, staffing), size, and system openness (academic affiliation). | - Gender-specific service availability in WHCs was comparable to that of CWHCs with important exceptions in mental health, mammography and osteoporosis management. -WHCs were less likely to have same-gender providers (p < .05), women’s health training programs (p < .01), separate women’s mental health clinics (p < .001), separate space (p < .05), or adequate privacy (p < .05); however, they were less likely to have experienced educational program closures (p < .001) and staffing losses (p < .05) compared to CWHCs.