# DEPLOYMENT AND POST-DEPLOYMENT HEALTH EVIDENCE TABLE

Author | Sample Characteristics | Sample Size | Design/Objective | Main Measures | Main Findings
2007^28^ | Female and male service members who deployed to OIF and completed post deployment health assessments (PDHA) and possibly post deployment helath reassessments (PDHRA) | Females 23,194 Males 198,989 | Observational; To document the frequencies of self-reported symptoms of and provider referrals during PDHAs among service members who subsequently showed evidence of PTSD | Responses to PTSD-related questions of PDHA’s and medical referral experiences of Operation Iraqi Freedom (OIF) deployers who were diagnosed with PTSD within six months after return from deployment; and/or screened positive for PTSD on Post Deployment Health Reassessment (PDHRA) questionnaires. | -Among PDHA respondents, 24.9% were referred for health concerns of any type, 10.5% screened positive for PTSD, and 4.1% were referred for mental health concerns. Among PDHA respondents who were clinically diagnosed with PTSD within six months after deployment (n=2676), 54.7% had been referred for a health concern, 48.1% had screened positive for PTSD, and 27.0% had been referred for a mental health concern during their PDHAs. -Females were more likely than males to receive referrals for health concerns in general and for mental health concerns specifically. -However, females were not more likely to screen positive for PTSD during PDHAs. Female and male clinically diagnosed cases and possible cases (per PDHRA responses) of PTSD had a similar prevalence of screening positive for PTSD on their PDHA questionnaire.
2007^21^ | Female and male military members who completed deployments for OEF/OIF (n=865674) in 2001–2006 | Females 91,424 Males 774,240 | Observational; To estimate the natures and incidence of mental disorder- specific diagnoses during medical encounters in the US Military Health System among all recent redeployers from Afghanistan and Iraq. | Natures and incidence of mental disorder-specific diagnoses | 1) About 12% of deployers received at least one, and about 5% of deployers received more than one, mental disorder-specific diagnoses after deploying. 2) The demographic subgroups with the highest rates of any mental disorder diagnosis after deploying were females (cumulative incidence: 17.4%), separated/divorced individuals (cumulative incidence: 16.2%), and those of “other” race/ethnicities (cumulative incidence: 15.0%). Deployers who were in the active component, in the Army, younger than 20 years old, and currently or previously married were also significantly more likely than their respective counterparts to receive a mental disorder diagnosis after deployment.
Adler 2005^33^ | U.S. female and male soldiers in non-combat arms units deployed on a NATO peacekeeping mission to the Bosnia area of operations that included Hungary, Bosnia-Herzegovina, and Croatia | Females 1225 Males 2114 | Observational; To examine the effects of stressor duration (deployment length) and stressor novelty (no prior deployment experience) on the psychological health of male and female military personnel returning from a peacekeeping deployment | Correlations between demographics, deployment experience, and dependent variables by gender; length of deployment and mean scale score of depressive and posttraumatic stress symptoms by gender; deployment experience and mean scale score of depressive and posttraumatic stress symptoms by gender | Longer deployments and 1^st^-time deployments were associated with an increase in distress scores. However, the relationship between deployment length and increased distress was found only for male soldiers.
Araneta 2004^41^ | Military women who were admitted to military hospitals for pregnancy-related diagnoses between August 2, 1990 and May 31, 1992 | Females 1110 | Observational; (1) To enumerate Gulf-War (GW) exposed conceptions (2) characterize reproductive outcomes among GW- exposed conceptions and (3) to compare reproductive outcomes of GW-exposed pregnancies with postwar conceptions of women GW veterans and women nondeployed veterans who belonged to deployed units. | The number of pregnancies, number of postwar conceptions (both deployed and nondeployed), similarity of adverse reproductive outcomes, number of spontaneous abortions and ectopic pregnancies | Gulf War-exposed conceptions and nondeployed conceptions had similar outcomes. However, GW veteran postwar conceptions were at increased risk for ectopic pregnancies and spontaneous abortions.
Cavin 2005^36^ | Case series of 12 World War II spies | Females 5 Males 7 | Observational; To discover if there were two types of soldiers: those who never talked about the war and those who could not stop talking about it. | Discussion of PTSD symptoms and wartime excitement | 1) Three of 12 still had PTSD symptoms nearly 50 years later. Many of these veterans constantly talked about their war-time experience throughout adult life. 2) The majority of the 12, regardless of gender, still exhibited war excitement when discussing their roles in the war. For 11 of 12, they were still visibly excited by war talk. For 10 of 12, war bonding evoked more powerful feelings than subsequent social relationships. 3) This case series of interviews related to PTSD was unique because it was a mixed gender cohort; it includes men and women with the same stressors; the women in the OSS study are not sexual victims; the research focuses on high functioning vets; it differs from a focus on combat soldiers; and it is derived from sociological interviews, not medical studies.
Erbes 2007^15^ | Female and male OEF/OIF veteran enrollees (n=120) at one Mid- western VAMC who had returned within a six-month time frame, agreed to participate and completed a questionnaire | Females 17 Males 103 | Observational; To evaluate levels of PTSD, depression, alcohol abuse, and the associations with quality of life, and mental health service utilization among returnees from OEF/OIF. | Psychiatric distress levels (measured by PTSD symptoms, depression symptoms, and hazardous alcohol use), functional impairment, and service utilization | 1) PTSD levels (12%) were consistent with previous research while problematic drinking levels were also elevated (33%). 2) PTSD and alcohol abuse were associated with lower quality of life in multiple domains, even when controlling for depression. 3) Of those screening positive for PTSD, 56% reported using mental health services. Only 18% of those screening positive for alcohol abuse reported using such services. 4) No reported findings were identified as related to gender.
Farley 2006^29^ | Female soldiers seen at the 325^th^ Combat Support Hospital (CSH; Bagram Air force Base, Afghanistan) | Females 62 | Observational; To evaluate the value, unit cost, and medical effectiveness of providing specialized obstetric and gynecological care “far forward”, at echelon III [the combat support hospital (CSH)] in the operating theatre of Afghanistan during OEF, rotation 5. | Total # of female patient seen at the CSH, average distance traveled for treatment, mean travel times, time to appointment, and woman-hours lost from each unit | A total of 62 cases were seen at the CSH, where 57 total patients were seen at the CSH (echelon III) and 5 were sent to Germany for care (echelon IV or V). 88% of the soldiers seen were of enlisted rank, 9% were officers, and 3% were civilians. Three (60%) of the patients sent to Germany were of enlisted rank, 1 (20%) was of officer rank, and 1 (20%) was a civilian employee. The military unit branch of origin varied greatly. 7% of the patients seen at the CSH were seen for their annual well-woman examination, 68% for abnormal cervical cytology and colposcopies, and 25% for other conditions (including pregnancy, dysfunctional uterine bleeding, and pelvic pain). The majority of the patients seen at the CSH were from BAF. The average distance traveled (p<0.0001), mean travel time (p<0.0035), time to appointment (p<0.035), and total time lost from each unit was significantly different for those traveling to Germany versus the CSH.
Felker 2008^11^ | Female and male military service members presenting to a mental health clinic in Kuwait | Females 78 Males 214 | Observational; To (1) describe the feasibility of using well-validated, screening measures, and (2) describe demographic and clinical characteristics of a sample of OIF military personnel who sought mental health care while deployed. | PTSD assessment; depression, alcohol use disorders and life stressors | -A total of 19% of the sample subjects screened positive for post-traumatic stress disorder- related symptoms, 35% for a major depressive disorder, and 11% for severe misuse of alcohol. Significant levels of distress and functional impairment were reported by 58% of the sample. -Women represented a disproportionately high percentage of those presenting for care (27%). Female service members might represent a high- risk group.
Haas 2007^32^ | All women presenting to the obstetrics clinic for prenatal care appointments at Naval Hospital Camp Lejeune from Jan to Apr 2005 | Females 463 | Observational; To determine if having a partner deployed in the military during wartime increased the stress levels in pregnant women and to determine predictors of reporting higher stress | Relationship between having a deployed partner and stress levels in pregnant women | Over 88.2% of patients responded to the survey. Women with deployed partners more often reported higher stress levels than those with homeland partners (39.6% and 24.2%, respectively; p<0.01). Logistic regression revealed that having a partner deployed (OR 1.89, 95% CI 1.00–3.57, p=0.04), being active duty (OR 2.64, 95% CI 1.43–4.87, p=<0.01), advanced gestational age (OR 1.04, 95% CI 1.00–1.07, p=0.03) and having >1 child at home (OR 2.30, 95% CI 1.12–4.73, p=0.02) all predicted higher stress reporting. Having a support person present was protective against stress (OR 0.40, 95% CI 0.20–0.78, p=<0.01).
Helmer 2007^14^ | Female and male veteran convenience sample from OEF/OIF active duty and reserve components (n=56) who were clinic patients at one War Related Illness and Injury Center (WRIISC) | Females 11 Males 45 | Observational (retrospective chart review); To describe the health and exposure concerns of a clinical case series of OEF/OIF veterans and compare findings between active duty and reserve components. | Physical health concerns (e.g., genitourinary concerns), exposure concerns (e.g., depleted uranium, multiple vaccinations, and poor air quality from burning trash), mental health concerns (e.g., PTSD) | 1) Compared to reserve veterans, most active duty veterans were male, single, and young. 2) Environmental exposure concern specific to the burning of trash and feces was higher among reserve veterans (43.6% vs. 11.8%; p=.02). 3) Physical and mental health concerns were similar between the two groups. 4) A comparison of genitourinary concerns between men (80% of our case series) and women (20% of our case series) did not demonstrate a significant difference by gender.
Hoge 2007^13^ | Female and male Iraq veterans, from four Army combat infantry brigades, surveyed 1 year after their return from deployment | Females 80 Males 2783 | Observational; This study evaluated the association of PTSD with physical health measures among Iraq war veterans 1 year after their return from deployment with control for combat injury. | Past month symptoms of PTSD, depression, alcohol misuse, self-rated health status, sick call visits, missed work days, and somatic symptoms. | -Among all participants, 16.6% met screening criteria for PTSD. PTSD was significantly associated with lower ratings of general health, more sick call visits, more missed workdays, more physical symptoms, and high somatic symptom severity. These results remained significant after controlling for being wounded or injured. -The high prevalence of PTSD and its strong association with physical health problems among Iraq war veterans have important implications for delivery of medical services. The medical burden of PTSD includes physical health problems; combat veterans with serious somatic concerns should be evaluated for PTSD.
Hoge 2006^20^ | Female and male Army soldiers and marines who completed a Post-Deployment Health Assessment (PDHA) on return from deployments to OEF/OIF) and other locations (eg., Bosnia, Kosovo) | Females 32,500 Males 271404 | Observational; To determine the relationship between deployment to Iraq and Afghanistan and mental health care utilization during the first year after return and to evaluate lessons learned from the postemployment mental health screening effort, particularly the correlation between screening results and actual use of mental health services. | Screening positive for PTSD, major depression, or other mental health problems; referral for a mental health reason; use of mental health care services after returning from deployment; attrition from military services | 1) The prevalence rates of mental health problems and combat experiences were consistently higher following deployment to OIF than to OEF or other locations. Among OIF veterans, 23.6% of women reported a mental health concern compared with 18.6% of men. 2) Referral to mental health was strongly correlated with screening positive for a mental health problem on the PDHA. Hospitalization was significantly associated with deployment location and reporting a mental health concern on the PDHA. (3) OIF veterans used impatient and outpatient mental health services at higher rates after deployment than OEF veterans and service members who deployed to other locations.
Hoge 2004^17^ | Female and male OEF/OIF active duty military from 4 combat units (Army or Marine) | Females 63 Males 6117 | Observational; To (1) study the prevalence of mental health problems among members of the military personnel recruited from combat units before or after their deployment to Iraq or Afghanistan, and (2) identify the proportion of service members with mental health concerns who were not receiving care and the barriers perceived to accessing and receiving care. | Symptoms in the past month of major depressive disorder, generalized anxiety disorder, and PTSD; current stress, emotional problems, alcohol problems, or family problems; use of mental health services in past month or year; perceived barriers to use | -Military personnel returning from Iraq were more likely to report a mental health problem, interest in receiveing help, and use of mental health services. -Rates of PTSD were significatly higher after combat duty in Iraq than before deplyment. Significant associations were reported for major depression the misuse of alcohol.
Katz 2007^16^ | Female OEF/OIF veterans who were referred to a single Women’s Mental Health Center for individual psychotherapy | Females 18 | Observational; To determine whether: (1) women have increased emotional symptoms because of difficulties readjusting to civilian life and (2) women have a unique experience in war compared with their male counterparts. | clinician symptom rating; Military Sexual Trauma (MST); being injured in Iraq; witnessing others injured or killed; and relationships between readjustment, symptoms, and events | -Women who had MST had more symptoms and more difficulties with readjustment to civilian life than those without MST.
Lambert 2006^26^ | Female and males forming a case series | Females 1 Males 4 | Observational; To report a series of consecutive cases of PTSD affected combat veterans who were treated with the atypical antipsychotic agent aripiprazole (i.e., Abilify) | Sleep disturbances, nightmares, anxiety in crowds | The five cases combat-related PTSD treated with aripiprazole and either sertraline or cognitive-behavioral psychotherapy illustrate a significant improvement, but not total resolution of symptoms in most cases.
Lapierre 2007^22^ | Female and male active duty soldiers, who participated in a reintegration training program after returning from Iraq or Afghanistan | Females 263 Males 3826 | Observational; To identify rates of posttraumatic stress and depressive symptoms in soldiers returning from war | Self-reported levels of depressions, posttraumatic stress, and life satisfaction | 1) Women comprised only a small sample (6%). 2) After deployment, about 44% of study participants reported clinically significant depressive and/or posttraumatic stress symptoms. Soldiers returning from Iraq reported somewhat more mental health problems and treatment seeking than soldiers returning from Afghanistan. 3) Being separated or divorced (vs. married) was associated with increased reports of post- traumatic stress and depressive symptoms. Compared to NCOs and officers, junior enlisted soldiers reported more posttraumatic and depressive symptoms. 4) Female participants were more likely to report depressive symptoms; however, gender was not a predictor for posttraumatic stress symptoms for either sample (OIF and OEF). 5) Soldiers seek help for the symptoms; however, only 16% of OIF participants and 13% of OEF participants with symptoms did so.
Lindstrom 2006^35^ | Active-duty enlisted Navy and Marine Corps females in combat support and noncombat support occupations | Females 73,777 | Observational; To conduct an exploratory study to develop a baseline assessment of the mental health hospitalization rates of military women working in newly gender-integrated combat support occupations prior to the onset of the wars in Iraq and Afghanistan | Relationship between number of hospitalizations in combat and non- combat support and mental disorders (e.g, substance abuse disorders, adjustment disorders, mood disorders, etc). | Using Cox regression to adjust for all variables in the model, results indicated that women working in combat support occupations were less likely (HR 0.64, 95% CI 0.53–0.77) to be hospitalized for a mental illness compared with women working in noncombat support occupations. The study also reported that older women were slightly more likely to have a mental health hospitalization (HR 1.21, 95% CI 1.04–1.41) compared with women in the youngest age category, ≤19 years. Additionally, white women were significantly more likely to have a mental health hospitalization when compared with black women (HR 1.41, 95% CI 1.24–1.60).
McNulty 2005^25^ | Female and male active duty Navy service members deployed on aircraft carriers during OEF/OIF in 2002–2003 | Females 259 Males 1182 | Observational; To describe the healthcare needs and perceived stressors of active duty members deployed to Iraq during the predeployment, middeployment, and postdeployment phases. Stress & HC needs during Navy deploy | Member well-being, adaptation, coping, anxiety, stress, and health care needs | Many variables predicted extreme anxiety during deployment, including middeployment phase, age under 25 years, being childless, nonattendance at church, being enlisted, zero- or one-deployment history; no high school education, and being currently in counseling. Active duty members in all phases of deployment had equally disturbing levels of anxiety. All phases reported suicidal ideation at alarming rates (2.4% in predeployment, 4.9% in mid-deployment, and 3% in postdeployment).
Pierce 1999^42^ | Stratified, random sample of US Air Force military women selected from a Department of Defense database who served in Operation Desert Shield or Desert Storm | Females 525 | Observational; To provide baseline health information on a randomized sample of military women serving during the Persian Gulf War. | Prevalence of gender specific health problems, rate of health care utilization, satisfaction with military and civilian care during respondents’ military careers | -The most prevalent gender-specific problems were problems during pregnancy (41%), urinary tract infection (34%), headache (33%), and menstrual irregularities (32%) and abnormal Pap smear (27%). - Of note, many women did not seek health care for their problems. -In this overall group, 76% reported using military health care, 41% used civilian health care, and only 3% reported using the VA for care. -Overall, for 15 of 18 conditions, satisfaction ratings were higher for civilian care.
Pierce 1997^39^ | Stratified, random sample of US Air Force military women selected from a Department of Defense database who served in Operation Desert Shield or Desert Storm | Females 525 | Observational; To describe the effects of deployment and military service during the Persian Gulf war on women’s physical and emotional health | General physical health, gender specific and reproductive health, 18 symptoms of gender-specific health problems, subscales for anxiety, depression, somatization, and PTSD | Women deployed to theatre reported significantly more general as well as gender-specific health problems than did women deployed elsewhere. A cluster of common health problems included: skin rash; cough; depression; unintentional weight loss; insomnia; and memory problems. Women serving in theatre also reported a significant increase in several gender-specific problems compared to women deployed elsewhere.
Rundell 2006^19^ | Female and male OEF/OIF active duty military evacuated from theatre due to psychiatric conditions (n=1264) | Females 237 Males 1027 | Observational; To characterize the demographic composition, clinical diagnoses and clinical dispositions given to OEF/OIF psychiatric patients seen at the Landstuhl Regional Medical Center (LRMC). | Demographic information, clinical diagnosis, and clinical dispositions for the LRMC OEF/OIF psychiatric patients | 1) Psychiatric evacuees were more likely to be female, African-American of Hispanic, under the age of 31 years, enlisted and National Guard Reserve, as opposed to active-duty military. 2) More than 80% of patients were evacuated during the first 6 months, compared with only 17% during the second 6 months of deployment; less than 5% of the LRMC psychiatric evacuees were returned to OEF/OIF duty. 3) Women were overrepresented as psychiatric evacuees almost by a factor 2, which suggests the possibility that there are gender-specific risks that increase the possibility of becoming a psychiatric evacuee.
Seal 2008^24^ | Female and male veterans with military separation dates after September 11, 2001 presenting for care at one VA medical center or its community based clinics | Females 83 Males 750 | Observational; To determine the frequency and predictors of implementation of the VA postdeployment screen; the proportion of veterans with positive screens for PTSD, depression or high risk alcohol use; the proportion of veterans seen in a VA mental health clinic within 90 days and beyond | PTSD screen, depression, alcohol use, and completion of a mental health appointment for those screening positive | Postdeployment screening was more likely in veterans who had a primary care visit versus other settings (72% vs 12%; adjusted odds ratio [AOR]=13.3; 95% confidence interval [CI]=8.31, 21.3) and for those seen at a VA community clinic rather than at the medical center (87% vs 37%; AOR=3.56; 95% CI=1.78, 7.11). African American veterans of OIF or OEF were less likely to be screened than were White veterans (29% vs 49%; AOR=0.45; 95% CI=0.22, 0.91). The likelihood of a follow-up mental health visit within 90 days of screening was increased for veterans who were seen in a VA community clinic versus the medical center (AOR=6.08; 95% CI=1.56, 23.6) and for those seen in primary care versus another outpatient setting (AOR=19.4; 95% CI=1.30, 290).
Seal 2007^12^ | Female and male veterans, serving in OEF/OIF, and new users of VA health care system | Females 13,652 Males 90,117 | Observational; To (1) describe the proportion of OEF/OIF veterans seen in VA facilities who received one or more mental health and/or psychosocial diagnoses and the timing and clinical setting of first mental health diagnoses, and (2) identify subgroups of OEF/OIF veteransat high risk for receiving mental health diagnoses after returning from military service. | Mental health diagnoses and psychosocial problems | Of 103,788 OEF/OIF veterans first seen at VA health care facilities following OEF/OIF service, a quarter received mental health diagnoses, and more than half of these veterans were dually or multiply diagnosed. The most common military service–related mental health diagnosis was PTSD. When psychosocial problems were considered, overall, nearly a third of OEF/OIF veterans were classified as having either mental health diagnoses and/or psychosocial problems. Of veterans receiving mental health diagnoses, the majority were diagnosed on or within days of their first VA clinic visit. Most initial mental health diagnoses occurred in non-mental health settings, particularly in primary care settings. Minimal absolute differences were found between
Smith 2008^10^ | Female and male military service members previously deployed to Iraq and Afghanistan, exposed to combat, who had no PTSD at baseline assessment | Females 890 Males 4469 | Observational; To conduct a prospective investigation of the relationship between prior assault and PTSD in a military cohort deployed to combat in Iraq and Afghanistan. | PTSD assessment, assault history, assault history, behavioral risk factors, and combat exposure. | -New-onset PTSD symptoms or diagnosis among deployed military reporting combat exposures occurred in 22% of women who reported prior assault and 10% not reporting prior assault. -Among men reporting prior assault, rates were 12% and 6%, respectively. -Adjusting for baseline factors, the odds of new-onset PTSD symptoms was more than 2-fold higher in both women and men who reported assault prior to deployment.
Smith 2008^23^ | Female and male active duty military enrolled in the Millenium Cohort Study surveyed before and after the wars in Iraq and Afghanistan | Females 13849 Males 36279 | Observational; To investigate prospectively the effect of military deployment and self reported exposure to combat on new onset and persistent symptoms of PTSD in a large population based military cohort | Self-reported PTSD symptoms (PCL-C); | Over 40% of the cohort was deployed between 2001 and 2006; 24% deployed for the first time in support of the wars in Iraq and Afghanistan. Incidence rates of 10–13 cases of PTSD per 1000 person years occurred in the millennium cohort. New onset self reported PTSD symptoms or diagnosis were identified in 7.6–8.7% of deployers who reported combat exposures, 1.4–2.1% of deployers who did not report combat exposures, and 2.3–3.0% of nondeployers.
Smith 2007^38^ | Large, longitudinal, population-based cohort of active duty military servicemen and women with oversample of those recently deployed, female or reserve/guard members. | Females 20106 Males 75413 | Observational; To evaluate the baseline functional health status of a large population- based military cohort | Physical and mental health component scores (PCS and MCS) of the SF36-V | -The baseline physical and mental health component scores of a military cohort is slightly more favorable than that of the same-age, same-sex U.S. general population. -Factors associated with more favorable health status were male gender, marriage, higher education, higher military rank, and Air Force service. Combat specialists had similar health status compared to other military occupations. -Gender-specific results showed increasing age was associated with more favorable MCS scores and less favorable PCS scores among active duty and reserve/guard women. Similar results were found among men.
Smith 2007^40^ | Subset of female responders to the Millennium Cohort questionnaire (derived from all US Military personnel serving in October 2000) | Females 20139 | Observational; (1) To establish the degree of concordance between self-reported occupation and the electronically maintained personnel occupation data. (2) To describe occupational exposures among a current cohort of US military women. | (1) The reliability of self-reported occupation when compared with electronically maintained data; (2) odds of women in certain occupations (adjusting for demographic and military characteristics) to report particular exposures of concern (potentially toxic environmental exposures or disturbing experiences) | -Self-reported occupations were moderate to highly reliable when compared to electronic data. Health care specialists demonstrated almost perfect agreement, and trainees demonstrated poor agreement. -Occupation, age, education, pay grade, and service branch were significantly associated with reporting witnessing death, witnessing trauma, exposure to chemical or biological warfare, exposure to depleted uranium, and exposure to pesticides. (p<0.05) -After adjustment for demographic and military factors, deployment to SW Asia, Bosnia, or Kosovo (from 1998–2000), and deployment to the 1991 Gulf War, active-duty women health care specialists were significantly more likely to report witnessing death or trauma compared to combat specialists. -Active-duty women specialists in the field of electrical/mechanical equipment repair were significantly more likely to report witnessing death, exposure to depleted uranium, and pesticides compared with combat specialists.
Stecker 2007^27^ | Female and male National Guard soldiers who had served in OIF and screened positive for 1 or more mental health disorders | Females 2 Males 20 | Observational; To assess beliefs about mental health treatment in a group of soldiers newly returning from Iraq. | Seeking mental health treatment after returning from Iraq; normative and control beliefs about mental health treatment | Stigma was portrayed as a major disadvantage to treatment seeking. Yet most participants indicated that people would be supportive of treatment seeking. Reducing symptoms was a major advantage to care. Barriers included pride, not being able to ask for help, and not being able to admit to having a problem.
Stetz 2005^18^ | Female and male soldiers medically evacuated from theatre due to psychiatric conditions (n=5671; with 9% missing gender) | Females 912 Males 4264 | Observational; To present a snapshot of the main psychiatric reasons reported for medevacs during OEF/OIF. | Medevac cases from OEF and OIF; psychiatric diagnoses with ICD-9 codes; gender; military rank | Psychiatric diagnoses were the 2^nd^ leading cause of medevacs in OEF and 4^th^ leading cause in OIF. For medevacs from OEF, 18% of the troops were women, while in OIF, 16% of troops were female. The proportion of medevacs with psychiatric diagnoses by gender was 33% women for OEF and 17% women for OIF.
Thomson 2006^30^ | Female active, reserve and National Guard units deployed in Iraq or Kuwait for at least 3 months, but no more than 8 months | Females 251 | Observational; To assess women’s perceptions of health care delivery in OIF, specifically those receiving care at the echelon I and II level (front line and aid station). | predeployment screening, contraceptive method availability and side effects, accessibility of gynecological care, field hygiene counseling, and smoking status | All respondents were of reproductive age, except two. Irregular bleeding was the most common side effect among soldiers using hormonal contraception. Ortho Evra patches fell off in 58% of cases, 23% of soldiers changed contraceptive methods once they were in the field because of unavailability of their previous method, 21% of soldiers experienced some type of gynecological problems, and 44% could not access gynecological care. 26% of soldiers received predeployment menstrual hygiene counseling, and of those, 77% attempting cycle control succeeded. Almost one half of the respondents did not meet the cervical cytological screening practice guidelines supported by the American College of Obstetricians and Gynecologists.
Vogt 2008^31^ | Female and male active duty service members deployed to Iraq | Females 49 Males 640 | Observational; validation study; To validate 9 scales from the Deployment Risk and Resilience Inventory (DRRI) in a large sample of Operation Iraqi Freedom (OIF) army personnel diversified in occupational and demographic characteristics. | Reliability and validity of DRRI scales | Evidence for internal consistency reliability was quite strong and similar to that demonstrated in a sample of Gulf War I veterans on which these scales were originally developed and validated. In general, DRRI scales demonstrated reasonable to excellent values for coefficient alpha, suggesting that the item sets converged on a common construct. Significant gender differences emerged for 5 of the variables. Men reported greater exposure to combat and after- math of battle and more often reported being well prepared for deployment. Women reported greater perceived threat compared to men.
Vogt 2005^34^ | National sample of Gulf War I female and male veterans identified through the Manpower Data Center and VA Gulf War Health Registry, with an overrepresentation of women (25% women, 75% men) and representations from all branches of the military | Females 83 Males 233 | Observational; To examine deployment stressors to elucidate gender differences in war-zone exposure and identify gender- based differential associations between stressors and mental health outcomes. | Mission related stressors, inter- personal stressors, mental health outcomes (depression, anxiety, posttraumatic stress (PTSD) symptomatology) | The response rate was 66%, and women were slightly less likely to participate than men (56% vs. 67%). As deployment social support decreased, levels of depression increased for both women and men. However, the depression slope was much steeper for women. As levels of sexual harassment increased, levels of depression or anxiety increased sharply for men, and changed very little for women, possibly representing a stronger risk factor for men. For anxiety levels, both concerns about family disruptions and lack of deployment social support resulted in higher anxiety, especially for women.
Wolfe 1992^37^ | National sample of Vietnam veteran females who had participated in research conducted at the National Center for Post-Traumatic Stress Disorder. | Females 76 | Observational; To examine the status of PTSD in a cohort of women after the onset of Operation Desert Storm. | Changes in PTSD symptoms (in particular; re-experiencing, avoidance/numbing, and hyperarousal), and ratings on a series of broad-based psychological symptoms (SCL-90-R). | One-way ANOVAs indicated that the group of female veterans who had previously reported high levels of PTSD were significantly more susceptible to greater distress across all three PTSD ratings (p<0.001). Univariate tests showed significant differences between the two groups on all nine dimensions of the SCL- 90-R, (p<0.005).