# SEARCH STRATEGY

## WOMEN VETERANS HEALTH CARE – SEARCH METHODOLOGY

### SEARCH #1

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 2004-8/19/2008

SEARCH STRATEGY:

women* OR gender

AND

veteran*

AND

systematic[sb] OR meta-analysis OR metaanalysis OR women’s health services OR quality OR utilization OR patient satisfaction

NUMBER OF RESULTS: 260

### SEARCH #2

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 2004-8/19/2008

SEARCH STRATEGY:

“RELATED ARTICLE” SEARCHES ON THE FOLLOWING ARTICLES:

Med Care. 2003 Aug;41(8):950–61.

Gender Differences in service connection for PTSD.

Murdoch M, Hodges J, Hunt C, Cowper D, Kressin N, O’Brien N.

J Gen Intern Med. 2003 Mar;18(3):175–81.

Patient satisfaction in women’s clinics versus traditional primary care clinics in the Veterans Administration.

Bean-Mayberry BA, Chang CC, McNeil MA, Whittle J, Hayes PM, Scholle SH.

J Gen Intern Med. 2006 Mar;21 Suppl 3:S11–8.

To use or not to use. What influences why women veterans choose VA health care.

Washington DL, Yano EM, Simon B, Sun S.

J Gen Intern Med. 2006 Mar;21 Suppl 3:S82–92.

The state of women veterans’ health research. Results of a systematic literature review.

Goldzweig CL, Balekian TM, Rolón C, Yano EM, Shekelle PG.

AND

systematic[sb] OR meta-analysis OR metaanalysis OR women’s health services OR quality OR utilization OR patient satisfaction

AND

women* OR female* OR gender

NUMBER OF RESULTS: 133

### SEARCH #3

DATABASE SEARCHED & TIME PERIOD COVERED:

Web of Science SSCI, A&HCI – 2004-9/3/2008

SEARCH STRATEGY:

Topic=(women* OR gender)

AND

Topic=(veteran*)

AND

Topic=(systematic review* OR meta-analysis OR metaanalysis OR health services OR quality OR utilization OR patient satisfaction)

NUMBER OF RESULTS: 140

### SEARCH #4

DATABASE SEARCHED & TIME PERIOD COVERED:

Web of Science SSCI, A&HCI – 2004-9/3/2008

SEARCH STRATEGY:

“FORWARD SEARCHES” ON 4 ARTICLES IN SEARCH #2

NUMBER OF RESULTS: 48

NUMBER OF RESULTS BY ARTICLE:

Med Care. 2003 Aug;41(8):950–61.

Gender Differences in service connection for PTSD.

Murdoch M, Hodges J, Hunt C, Cowper D, Kressin N, O’Brien N.

12

J Gen Intern Med. 2003 Mar;18(3):175–81.

Patient satisfaction in women’s clinics versus traditional primary care clinics in the Veterans Administration.

Bean-Mayberry BA, Chang CC, McNeil MA, Whittle J, Hayes PM, Scholle SH.

13

J Gen Intern Med. 2006 Mar;21 Suppl 3:S11–8.

To use or not to use. What influences why women veterans choose VA health care.

Washington DL, Yano EM, Simon B, Sun S.

12

J Gen Intern Med. 2006 Mar;21 Suppl 3:S82–92.

The state of women veterans’ health research. Results of a systematic literature review.

Goldzweig CL, Balekian TM, Rolón C, Yano EM, Shekelle PG.

11

### SEARCH #5

DATABASE SEARCHED & TIME PERIOD COVERED:

Social Sci Abs, PsycINFO, WorldCat – 2004-9/4/2008

SEARCH STRATEGY:

kw: women* OR kw: gender

AND

kw: veteran*

AND

(kw: systematic and kw: review*) OR kw: meta-analysis OR kw: metaanalysis OR (kw: health and kw: services) OR kw: quality OR kw: utilization OR (kw: patient and kw: satisfaction))

NUMBER OF RESULTS: 176

NUMBER OF RESULTS BY DATABASE: Social Sci Abs (4), PsycINFO (134) WorldCat (42)