# SCREENER APPLICATION GUIDELINES

## Screener Application Guidelines

### Inclusion/Exclusion Criteria: (A) plus at least one of (B), (C), or (D)

- A: If women veterans are convenience sample and being a women veteran is not a unique characteristic for the study, should be STOP
- B: Needs separate results for women or women greater than 75% of the sample. Sex as a covariate does not count unless statistical beta shown.
- C: Study involves active duty military and involves a health condition or functional status that requires medical intervention FOR WOMEN
- D: “Topic is relevant to VA healthcare” TO WOMEN OR “how VA healthcare is delivered ” TO WOMEN
- D: If study is not an organizational study and it’s only inclusion is because of 1D, then it should be brought to the group for discussion

### Study Type

- Surveys are to be included as observational studies.
- Review articles must have methods section with sufficient detail to replicate to be classified as a systematic review.
- Clinical practice guidelines included under unclear/other.

### Sample size

- List number of women. Also, include full or total sample size.
- For surveys, use the number completed, not the number sent out.
- Identify whether sample is patients or other (e.g., site of care, etc)
- -Determine sample size from analysis, check the n used

### Setting

- Use multi-site if no other option is feasible, VAMC=Hospital, GLA=Integrated HCS

### Period of Service

- Do not use years of military service of study participants (1999, 2002, etc.) to determine period of service. Only identify period if included by article

### Topics

- Every article must have a topic
- For topics, consider access synonymous with availability
- Do not use predictor variables from the analyses to code the study for the screener
- MST/Sexual Assault and similar descriptions are to be categorized under the exposures categories
- Vulnerable populations include: Homeless, transgender, adults with cognitive impairment and SMI (serious mental illness)
- Cognitive behavioral therapy CBT → define as a clinical research topic
- Medication adherence to be categorized as health behavior

### Conditions

- For conditions: only identify those that are a main focus of the article, not adjusters
- Domestic violence should be categorized under General Trauma
- Diabetes should be categorized under Endocrinologic

General note: “grey literature” (theses and other unpublished/non-peer reviewed works) can be included if they pass the screener’s criteria