# STRUCTURED ABSTRACT FORM

## Women’s Health Structured Abstract

<<CITATION>>

Article ID:

■ Women’s health topic areas:
■ Study Design Category:
■ Period of Service:
■ Female Sample Size:
■ Total Sample Size:
■ Non patient sample:
■ Study setting (from where was study population drawn):
■ Year(s) of study or sampling timeframe:
■ Purpose of Study:
■ Outcomes Reported:

Study design/methods:

■ Study population (active duty, veterans, VAMCs, era, clinic patients, convenience sample, etc):
■ Women-focused or women as subset population:
■ Brief Summary of Methods: (describe what was measured, what intervention was performed, what was analyzed and how they did it):

Main findings:

■ other important items