# PEER REVIEW COMMENTS

Reviewer | Comment | Change
LAB | I noted three articles that may have been missed in your review: (1) Vernon SW, del Junco DJ, Tiro JT, Coan SP, Perz CA, Bastian LA, Rakowski W, Chan W, Lairson DR, McQueen A, Fernandez ME, Warrick C, Halder A, DiClemente C. Promoting regular mammography screening II. Results from a randomized trial in US Women Veterans. J NCI 2008;100:347–358; (2) McQueen A, Swank PR, Bastian LA, Vernon SW. Predictors of perceived susceptibility of breast cancer and changes over time; a mixed modeling approach. Health Psych 2008;27:68–77; (3) Chireau MV, Salz T, Brown H, Bastian L. Outcomes, Costs, and Utilization of Pregnancy-related care. Federal Practitioner September 2006: 20–30. The most important article is by Vernon et al (pdf attached to Email). It is the companion article to Del Junco ref #83 (described on page 25) and presents results of a large NIH-funded trial designed to improve mammography adherence. I think it should be listed as an important clinical trial. The other 2 articles (are also attached) include an assessment of breast cancer risk perception among women veterans and a pilot study of pregnancy outcomes among women veterans using the VA. | We agreed with the recommendations and have added these 3 articles to the review.
LH | I have struggled with the formatting/organization. I recommend changing your fonts to more explicitly help the reader stay on track with the section they are reading. It might help to have more subsections. I struggled with having all of the ptsd/mental health stuff in the deployment section. It seems to me you need a clear cut mental health section and that those studies should be located there. Also, in general, I think the deployment/post-deployment section is very difficult to read and confusing. A clearer cut font pattern might help with this. | We changed the size and font for the headers of each section and subsection to guide the reader more clearly through the report
LH | It is my view that there is too much reporting and too little synthesis in this report. I do not know the end user for this but if I were reading it or trying to use it for something what I would want is the bibliography at the end, perhaps organized more as I suggest above (more subcategories), with more synthesis in the text----really, kind of an expanded summary section. As an example, on page 26 there is a paragraph summarizing data on cvd risks. It might be more useful to expand this summary statement and note how little data there really are about cvd rf in women vets. I am struck by how little meaningful research has been done. | 1) Due to the descriptive nature of literature covering a population and not a disease, some of this synthesis technique is limited. 2) We expanded the CVD summary comments to inform the reader of the limited nature of the data. 3) We are also creating an online database of these articles, as well as those from the previous report, that may act as an interactive searchable bibliography.
LH | Brainstorming, the organizational structure that makes sense to me is as follows: a. Mental health---ptsd, substance abuse, mst; b. Access; c. Gender specific health care---reproductive, breast, etc; d. Quality of care; e. Deployment/post-deployment care; f. Health care delivery; g. Utilization; h. Health care outcomes/research; i. Maybe a specific oif/oef section. However, this is just brainstorming and I certainly don’t know the ltierature well enough to feel any confidence about this. Again-rather than just reporting the results line by line, it seems to me this report needs the synthesis. It wouldn’t matter to me if the paper was short if it provided meaningful summaries. You have all the data in the appendix. | Recommendations appreciated. Our general categories overlap with your suggestion. We plan to keep post-deployment and OEF/OIF sections separate from gen categories due to its special relevance with current veterans.
LH | I would add article titles and author names and maybe even the journal to the appendix tables 5–9 so readers can quickly figure out if they want to bother reading the results. | The current format is standard reporting style; the tables would be unwieldy otherwise.
PPS | Comprehensiveness: Last time, I had searched the PILOTS database on www.ptsd.va.gov to help out. PILOTS includes Medline, PsychInfo, and other databases and grey literatures, and indexes content according to a trauma-specific controlled vocabulary. For example, I believe the following articles I found thru PILOTS (quickly using the descriptors DE=female and (military personnel or veterans)) would be relevant but are not included. (1) An examination of family adjustment among Operation Desert Storm veterans Taft, Casey T; Schumm, Jeremiah A; Panuzio, Jillian; Proctor, Susan P Journal of Consulting and Clinical Psychology, vol. 76, no. 4, pp. 648–656, August 2008. (2) Alcohol use and alcohol-related problems before and after military combat deployment. Jacobson, Isabel G; Ryan, Margaret A K; Hooper, Tomoko I; Smith, Tyler Clain; Amoroso, Paul J; Boyko, Edward J; Gackstetter, Gary Dean; Wells, Timothy S; Bell, Nicole S. Journal of the American Medical Association, vol. 300, no. 6, pp. 663–675, August 13, 2008 And even PILOTS is not good enough, e.g., I found the following on PubMed (but not PILOTS) and would think it needs to be included: Distress and pain during pelvic examinations: effect of sexual violence. Weitlauf JC, Finney JW, Ruzek JI, Lee TT, Thrailkill A, Jones S, Frayne SM. Obstet Gynecol. 2008 Dec;112(6):1343–50. PMID: 19037045 [PubMed - indexed for MEDLINE] Maybe you found some of the articles I’m mentioning and decided to exclude them. If so, then I don’t think the inclusion/exclusion criteria are correct because I don’t see why you would not include a study on sexual trauma and pelvic exams in women | The articles located in the PILOTS database occurred at the end or after the search was completed in August 2008. They will be included in the next update to follow this one.
PPS | Timeliness: I think the report should be more current than 2008 because so much literature has emerged since 2008, particularly on younger veterans and service members, but also on older cohorts who are using VA in greater numbers. For example, in the quick search above (which probably should be expanded—our information scientist could advise you on the best way to do a comprehensive search for this topic), I found 31 articles 2004–2008 and 18 from 2009 to the present. I know the decision of where to cut is hard—we’re currently dealing with this in a meta-analysis—but at the end of 2010 I would think this should be current at least thru 2009. | We agree with your suggestion. A subsequent update will follow this one for additional literature review.
PPS | Topics: It seems like aging is not addressed much in the literature, even though this is an issue for VA; more broadly, there is very little known about trauma in older women. Should this maybe mentioned? I may have missed it. | Very few articles covered aging veterans beyond the studies on medications in patients >65. We will add this area as a current gap to our report.
PPS | I also wondered if there is a meta-issue worth mentioning, which is that people sometimes do not report data on women separately even when they could. | Yes, some articles had data analyses with results by gender but did not report on it. Gender was often used as a control variable in large sample analyses. This finding is now listed within the body of the report.
AGS | There is a difference in presentation style in the deployment section in that authors names are not noted whereas in subsequent sessions they are done when possible. This might be due to multiple authors cited in some cases. | We corrected this error and included author names in the deployment section.
AGS | It would have been useful for the investigators to have used the (Appendix I) screening form to comment within the text on the topics that did not meet with inclusion criteria and are deficits in our knowledge base or literature. For example, TBI or polytrauma work does not have a body of work that will benefit our understanding and care of women and I would also consider this as one of the ongoing gaps as well as the ones already identified (that are definitely on target). In short, including what isn’t done using this thorough screener is also as important as what is done and summarized. However, given how well done this is, perhaps this might be considered in a brief summary paragraph and be sufficient. Another example of what is missing is literature on cervical cancer (Pap smear) screening compliance in women veterans and so forth. | We have added your suggestions (TBI, poly trauma data by gender, invasive exams among veteran women or women w trauma) to a current gaps in the literature section for the report.
SF | P6, Methods, criterion A: “(a) included women veterans,…” So, if a study included WV but did not specifically examine gender effects, was the study included? | Yes, a study was included if it included women vets but was not specifically done to examine gender effects.
SF | P6, Methods, criterion C: “(c) relevant to VA healthcare or how VA care is delivered to women…”: First, do you mean, “relevant to VA women’s healthcare?” Second, it seems like both clauses are talking about health care delivery, but I’m wondering if the first clause is supposed to be about health rather than delivery? Should it say, “relevant to women veterans’ health or how VA care is delivered to women”? | Yes, we modified the phrasing using your suggestions.
SF | P7, Conclusions: I’m thinking you may be able to add a couple good “soundbites” in bold or italics, which may subsequently be picked up by the press or policymakers when they are referring to your report. For example, at the end of the first paragraph of conclusions: “Therefore, more women veterans health articles have been published in the past 5 years than in all of the 23 years before that.” At the end of the last paragraph, “Therefore, the past 5 years have seen substantial alignment between priority areas for women veterans health research and the topic areas being pursued.” | Thank you! These soundbite statements were added to the report with bold font.
SF | P8, PA1: does 44% refer to users or enrollees? | Corrected, enrollees.
SF | P9, PA1: did you use “military” (or equivalent) at all in the search strategy? | Did not use “military”. Only used “Veterans”.
SF | P13 Box showing 295 rejected, 151 abstract/title rejections: could potentially show the breakdown the same way you do in the lower box of 185 rejected (ie why the abstract/title was rejected) | Title and abstract rejections were done by team consensus in a meeting. The other rejections were decided using the formal screen and for a specific reason using 2 physician reviewers.
SF | P16 PA1: change “complete routine screening” to “complete routine gynecological screening” | Corrected.
SF | P17 PA4: I think the sentence could be inverted so the finding comes before the interpretation: “A key finding is that psychiatric diagnoses were common for both OEF and OIF evacuations, suggesting the need for DOD and VA to…” | Corrected.
SF | P20 PA1: Is a comma missing after “inpatient quality”? | Corrected.
SF | P21 PA1 (last line): should “perceptions” be “expectations”? | Yes, corrected.
SF | P25 PA1: I don’t understand this sentence (“abstain or say no to sex” shows up twice in the sentence, and I don’t understand what “compared to” means here.)
SF | P25 PA4: This mentions a “mammogram intervention”; it would be nice to have a few words re what kind of intervention. | 1 sentence explanation added.
SF | P26 PA2: Same thing, would be nice to have a few words describing the employee intervention. | 1 sentence explanation added.
SF | P26 PA5: Refers to “sexual trauma patients” and “mental health/PTSD patients.” Would avoid this terminology through- out—I imagine that some patients may read the report, and may be more comfortable with terminology like, “patients with a history of sexual trauma”, “patients with mental illness [or mental health conditions]” etc. | Corrected phrasing as suggested.
SF | P31 PA3: “prevalence of violence” should be “prevalence of prior exposure to violence” | Corrected phrasing.
SF | P35 PA2: refers to “VA’s first women’s health research agenda” without explaining what this is. | First women’s health research agenda is now explained.
SF | P35 PA4: Says that topic areas map to VA priorities. One idea for an appendix could be to list published VA priority areas and then map studies to them. Probably too involved at this late stage of report preparation, but could be something to consider for future. | Will consider adding this appendix piece to next update.
SF | P36 PA4: After the end of the sentence “subgroup analyses of women in VA” could add, “and demonstrates that it is feasible to conduct robust clinical trials in women veterans” | Corrected. Info added.
SF | P36 PA5: This mentions step 4 in the VA QUERI model; this comes a bit out of nowhere; consider including the QUERI model as an appendix? Again, probably too involved at this late stage, but in a future report it could be interesting to map studies to the QUERI model. | QUERI model reference was removed from this section.
SF | P36 PA6: I think the word “not” is missing, i.e., “VA studies have NOT yet made their mark…” | Corrected. “not” added.
SF | P36 PA7: I think point #1 should be preceded by the word “limited” and could also talk about combos of diseases, e.g., “Limited clinical and intervention outcome data for chronic physical or mental health conditions and complex combinations of diseases”. In addition to these three points, would you also want to comment on the need for info about the impact of new re-design efforts (PCMH, WCHIP)? | Corrected. “limited” added.
SF | References: I notice that a few are from pre-2004 (eg references 35, 77). Is that intentional? | If articles from prior years were sent to us from VA investigators or from culling other citations, we included them in order to be as comprehensive as possible.
SF | When you mention odds ratios, could indicate whether they are adjusted (which could be done compactly by using the abbreviation AOR). | We changed ORs to AOR’s where appropriate.
SF | Something to consider for the next time you do this is whether to also include methodological studies as a category. Hopefully some people will be publishing on what it takes to do women’s health research in VA. | We will keep this consideration in mind for the next women vet lit update.
SF | Another thing to consider for the future would be whether to include the Impact Factor of journals in the table showing all articles. I have mixed feelings about this, because there are questions about how these impact factors are calculated. But, the reason I raise it is because there had been concern about whether research on women veterans is appearing in less visible journals, and it could be interesting to know whether this is starting to improve. | We decided not to include the impact factor of the journal to avoid the politics of publications.
SF | I notice that in some places in the document, important limitations of a study are mentioned, along with the findings. I thought they way you did that was effective. If anything, I would like to see that even more (or even having a limitations column in the Table), because of the concern that people who read this will cite conclusions of studies without understanding the caveats. However, in addition to being more work than is feasible at this point, that would make the report long and cumbersome. One idea might be to comment briefly on this issue early in the document, i.e., that each study has to be interpreted subject to limitations and it is not feasible to include all the caveats and limitations in this document, so before citing the findings the reader should refer to the source article. | We decided to briefly comment on this issue in the report. It is now included in the methods/results section.