# RESULTS

We organize the results into an overview describing the literature flow and key characteristics of the included systematic reviews, followed by brief executive summaries for each condition. In each summary, we describe the reviews, general applicability of results to women, and reporting of sex effects. Descriptions of overall treatment effects reported by reviews that did not conduct sex-specific analyses are summarized in Appendix E (depressive disorders), Appendix F (diabetes), and Appendix G (chronic pain).

## LITERATURE FLOW

The literature search identified 2531 unique citations from a combined search of MEDLINE, the Cochrane Database of Systematic Reviews, and the bibliographies of umbrella reviews. After applying inclusion/exclusion criteria at the title-and-abstract screening level, 582 were retrieved for full-text review. Of these, 269 did not meet eligibility criteria. Of the 313 remaining eligible reviews, 45 diabetes reviews were examined for sex and gender terms and found to be negative; these 45 were not abstracted further. The remaining 268 systematic reviews were retained for full data abstraction (Figure 1).

Figure 1 Literature flow diagram

* We performed a keyword search for sex and gender terms on 45 of the 159 eligible diabetes reviews. The search was negative, which indicated sex or gender was not addressed in these articles. These 45 were thus not abstracted further, leaving 114 diabetes reviews for full data abstraction.

Unless otherwise indicated by the specific term “study” or “RCT,” all results apply to these 268 systematic reviews, to which we refer to hereafter as “reviews.” Appendix B contains details of the search strategies, and Appendix H provides a full alphabetical bibliography of the reviews included for each condition.

Of the 268 reviews that were fully abstracted, 86 addressed interventions for depression, 114 addressed interventions for type 2 diabetes, and 68 addressed interventions for the 3 types of chronic pain: CLBP (n=26), FM (n=34), and knee OA (n=8). Thirty-seven abstracted reviews (14%) originated from an organization known for high-quality reviews. There were more chronic pain reviews (25%) from these organizations than depression or diabetes reviews (11% each). The majority of abstracted reviews – 86% for depression, 61% for diabetes, and 84% for chronic pain – were restricted to RCTs.

Among fully abstracted reviews for all conditions other than fibromyalgia, only half (48%) summarized the gender distribution of the populations of the included studies. Sex effects were reported in only 30 of the 313 eligible reviews (10%) for all conditions. IPD meta-analysis—the method best suited to evaluating moderating variables such as gender—was rarely used (n=16 of 268 abstracted reviews, 6%)

## DEPRESSIVE DISORDERS

### Overview

The 86 reviews most frequently evaluated interventions for a range of depressive disorders (n=43) or major depressive disorder alone (n=29). Reviews evaluating treatments for relapse prevention, treatment-resistant depression, persistent depressive disorder (dysthymia), and subsyndromal depression were much less frequent (n≤7 for each). The most frequently evaluated interventions were psychotherapy (n=44) and antidepressant medications (n=24). Four of the psychotherapy reviews evaluated internet-delivered therapy. Eight reviews evaluated the effects of combined psychotherapy and antidepressant medication, and 7 reviews evaluated exercise, including one focused on yoga. Quality improvement interventions and guided self-help were reviewed infrequently.

The eligible reviews included from 3 to 243 primary studies, and all but 13 reviews restricted inclusion to randomized controlled trials (RCTs). Nine reviews originated from an organization known for high-quality systematic reviews.32-40 Fifty-two of 86 reviews (60%) reported the sex distribution of patients enrolled in the primary studies. When reported, women constituted the majority of participants for all of the interventions examined. However, relatively few of the recent, large systematic reviews evaluating psychotherapy or the combination of psychotherapy and antidepressants reported the sex distribution of the primary studies. Similarly, the minority of reviews addressing subsyndromal depression or relapse prevention reported the sex distribution of the primary studies.

Figure 2 shows a heat map of the number of primary studies evaluated in the largest review for each depressive condition–intervention dyad. Darker red indicates more primary studies and lighter red indicates fewer studies. Most reviews used quantitative analyses (ie, meta-analyses) to evaluate intervention effects. Ten reviews used IPD meta-analyses,41-50 a statistical method that is particularly well-suited to evaluating moderator effects such as sex.

Figure 2 Number of primary studies included in largest review for each condition–intervention dyad

Note: Combined refers to medication plus psychotherapy.

### Systematic Reviews: Reporting of Sex Effects for Depression Interventions

Of the 86 reviews, 14 (16%) reported results about sex effects (Figure 3). Sex effects were evaluated most frequently in reviews of antidepressant medications. One review focused on persistent depressive disorder,51 and the remainder included a broad range of depressive disorders or major depressive disorder. Sex effects were explored using meta-regression and less frequently using qualitative analyses. Only 3 reviews41,48,50 used IPD meta-analyses to explore sex effects. Next, we describe key findings from these reviews by depression intervention.

Figure 3 Number of reviews reporting sex effects for depression interventions

Note: Combined refers to medication plus psychotherapy.

Psychotherapy. Four reviews used meta-regression to evaluate sex effects.37,52-54 In a review of 53 trials, cognitive behavioral therapy (CBT) was found to be more effective as the proportion of women enrolled in the trial increased, but the effect was small.52 This finding was supported by another review,54 but no differential sex effect was found when CBT was compared with pharmacotherapy.37 Sex was not associated with treatment effects for short-term psychodynamic therapy.53 A fifth review evaluated sex effects qualitatively.55 This review identified a single study supporting greater efficacy for pharmacotherapy than psychotherapy for infertile women with depression (Hedges' g -0.94, CI -1.47 to -0.41).

Antidepressants. Six reviews reported sex effects.34,48,50,56-58 In an IPD meta-analysis, women treated with duloxetine showed small additional benefit compared with men on the Sheehan Disability Scale (n=6; -0.99, CI -1.91 to -0.07).48 Another IPD meta-analysis of desvenlafaxine trials reported that sex and baseline social impairment predicted some outcomes, but detailed results were not given.50 A comprehensive review conducted by an EPC that used multiple treatment comparison meta-analyses did not show differences in antidepressant treatment effects as a class by age, sex, ethnicity, or comorbid conditions.34 However, the authors noted that most studies did not address differences in efficacy or effectiveness between men and women. Limited data on adverse effects suggested that men treated with paroxetine were at higher risk for sexual dysfunction than women were, and that women receiving paroxetine compared with sertraline may be at higher risk for sexual dysfunction. Overall, adverse effects of antidepressants for men and women were similar.

Other reviews evaluated single drugs or antidepressants in older adults. A review restricted to sertraline and venlafaxine found that women showed small additional benefit compared with men when treated with venlafaxine.58 One review used meta-regression to evaluate the association between the proportion of men enrolled and treatment effects.56 In older adults with a depressive disorder, selective serotonin reuptake inhibitors (SSRIs) were somewhat less effective in men than in women at 3 of the 5 short-term follow-ups assessed.

Combined antidepressants and psychotherapy. A single review used meta-regression to evaluate the association between the proportion of women enrolled and the effects of combined treatments.51 In patients with dysthymia, sex did not moderate the effect of psychotherapy plus antidepressants compared with antidepressants alone.

Quality improvement. One review using meta-regression analysis found no important difference between studies that enrolled a majority of females compared with a majority of males.59

Self-help. A single review used IPD meta-analysis to evaluate sex effects in primary care patients with a diagnosis of depression or elevated symptoms on a self-report scale.41 Intervention effects did not vary by sex.

Other interventions. Sex effects were not examined in reviews of exercise or interventions for subsyndromal depression, interventions to prevent relapse, or interventions for treatment-resistant depression.

In summary, sex effects were examined infrequently, and the methodology most often employed (meta-regression) was suboptimal for drawing valid conclusions. Small sex effects were found for some antidepressants and psychotherapy, generally favoring better outcomes in women.

### Primary Studies: Reporting of Sex Effects for Depression Interventions

We selected a sample of primary studies included in the eligible systematic reviews that randomized at least 75 patients per treatment arm to determine if these studies evaluated and reported treatment effects by sex. Reviews of quality improvement interventions40 and psychotherapy60 were used for this analysis because we did not identify any IPD meta-analyses for these high-priority interventions.

We examined 21 clinical trials evaluating collaborative care interventions (an approach to quality improvement) for depressive disorders. The number of patients randomized ranged from 153 to 1801. One trial enrolled only women,61 and 5 enrolled Veterans.62-66 Of the 21 trials, only 2 evaluated subgroup effects by sex and found no effect on outcomes.67,68

Ten of the 92 studies (11%) included in the review60 randomized at least 75 patients to psychotherapy and to a comparator arm. Sample sizes in these studies ranged from 177 to 903. Two trials enrolled only women,69,70 and none enrolled Veterans. Only one trial potentially evaluated sex as a moderator, stating “no demographic characteristic … moderated time to remission.”71

## DIABETES

### Overview

We conducted full data abstraction for 114 reviews evaluating diabetes. Of 159 eligible reviews, we examined all medication studies and prioritized for full abstraction those that were most likely pertinent and/or were positive by text searching for keywords related to sex effects. We fully abstracted reviews for all other interventions. Among all eligible reviews, the most frequently evaluated interventions were medications (n=120), while fewer examined exercise (n=14) and mixed psychoeducation and behavioral interventions (n=6). Twelve reviews examined the effects of bariatric surgery. Dietary (n=4) and quality improvement interventions (n=3) were reviewed less frequently.

Abstracted reviews included from 0 to 347 primary studies, and 70 (61%) were restricted to RCTs. Twelve reviews (10%) originated from an organization known for high-quality systematic reviews.72-83 Figure 4 shows the number of primary studies evaluated in the largest systematic review for each intervention category. Most reviews (n=101; 89%) used quantitative analyses (ie, meta-analyses) to evaluate intervention effects. Only 5 reviews used IPD meta-analyses, and all of these evaluated medications.

Figure 4 Number of primary studies included in largest reviews of diabetes interventions

Overall, 48 reviews (42%) reported the proportion of women included in primary studies, but this varied widely by intervention. Most reviews on bariatric surgery (n=9, 75%) provided information on inclusion of women, while about half of reviews on exercise (n=6, 43%) and mixed behavioral interventions (n=3, 50%) did so. Somewhat fewer medication reviews (n=30, 40%) reported on inclusion of women, and none did so for diet or quality improvement interventions.

### Systematic Reviews: Reporting of Sex Effects for Diabetes Interventions

Of the 159 eligible reviews, 13 (8%) reported results on sex effects (Figure 5). Additionally, 6 reviews examined the risk for various types of cancer associated with different diabetes medications (eg, metformin and insulin), and included estimates for breast cancer risk.84-89 Finally, one review proposed to evaluate oral medications for women with preexisting diabetes or impaired glucose tolerance, but despite an adequate search strategy, found no eligible articles.82

Figure 5 Number of reviews reporting sex effects for diabetes interventions

Sex effects were reported most frequently in reviews of medications (n=10).90-99 Two reviews examined sex effects on diabetic remission after bariatric surgery.100,101 One review evaluated a range of psychoeducation interventions for minority women with diabetes and provided qualitative syntheses for various outcomes.102 Sex effects were most often explored using meta-regression (n=8). Only 3 reviews91,96,97 applied IPD meta-analyses to explore sex effects; all evaluated dipeptidyl peptidase-4 (DPP-4) inhibitors and included data only from industry-sponsored studies. Sex effects were not examined in reviews of supervised exercise, diet, or quality improvement. Next, we describe key findings from reviews reporting sex effects by diabetes intervention.

Psychoeducation and mixed behavioral interventions. Of 6 eligible reviews, one examined the effects of diabetes self-management education in black and Hispanic women, focusing on specific intervention features associated with positive results.102 This review included 10 RCTs and 3 cohort studies with comparators. Qualitative syntheses were reported for multiple outcomes, including HbA1c (3 of 10 applicable studies showed positive effects). Intervention features were organized into 9 categories (eg, intervention setting, frequency of sessions, and mode of delivery). Multiple features in each category were associated with improvements in various outcomes.

Medications. Of 120 eligible reviews addressing medications, 10 reported sex effects.90-99 Two focused exclusively on adverse effects, with one evaluating risk for bladder cancer associated with pioglitazone92 and one evaluated fracture risk associated with sulfonylureas.95 The review examining the risk of bladder cancer associated with pioglitazone found similar estimates of increased risk in men (HR 1.64, CI 1.01 to 2.67) and women (HR 1.69, CI 0.64 to 4.47), although only the results for men reached statistical significance.92 The review on fracture risk associated with sulfonylureas included 21 eligible studies and reported results from a single RCT showing that there was decreased fracture risk for sulfonylureas compared with thiazolidinediones in women (RR 0.37, CI 0.23 to 0.61) but not in men (RR 0.85, CI 0.52-1.40).95

The remaining 8 reviews investigated various outcomes, including glycemic control, cardiovascular events and/or mortality, and risk for hypoglycemia.90,91,93,94,96-99 Single reviews evaluated multiple classes of medications,90 insulin therapy,93 and metformin,94 while 5 reviews addressed incretin mimetics.91,96-99 The review on 8 medication classes included 218 RCTs; sex was evaluated as a source of heterogeneity and no association was found.90 One review evaluated the effect of short-term intensive insulin therapy on b-cell function, insulin resistance, and long-term remission, and identified 7 eligible studies; the proportion of men was associated with study heterogeneity, and improvement in insulin resistance decreased with increasing male representation.93 The review addressing the efficacy of metformin for preventing cardiovascular events and mortality included 35 RCTs and found no significant effect for cardiovascular events or survival.94 However, when limiting the analysis to trials that evaluated metformin monotherapy (n=4), there was significantly decreased risk for all-cause mortality with metformin use (Mantel-Henzel OR 0.55, CI 0.36 to 0.89) and significantly increased benefit in trials with more women (slope -0.039, CI -0.076 to -0.003).94

Among 5 reviews examining incretin mimetics, one evaluated both glucagon-like peptide 1 receptor agonists and DPP-4 inhibitors, and included 38 RCTs.99 This review examined hemoglobin A1c (HbA1c), weight, and hypoglycemia for exenatide, liraglutide, vildagliptin, and sitagliptin; adjusted analyses with key study information (eg, age, sex and study duration) did not change the results, and most covariates were not associated with significant effects.99 One review of DPP-4 inhibitors included 43 RCTs and also evaluated glycemic control, weight, and hypoglycemia; multiple covariates (eg, sex and study duration) were employed in meta-regression and none had a significant effect.98 Lastly, 3 reviews of DPP-4 inhibitors applied IPD meta-analyses to data from industry studies.91,96,97 Using data from 8 RCTs, one review reported subgroup analyses showing different point estimates for risk of death from cardiovascular disease for men (HR 0.25, CI 0.10 to 0.60) and women (HR 0.96, CI 0.21 to 4.37) when comparing linagliptin with placebo, glimepiride, or voglibose.97 Another review evaluated linagliptin among participants with and without renal dysfunction and included data from 3 RCTs; both men and women had improved glycemic control with linagliptin, with no evidence of interaction effect for sex and treatment efficacy.91 The third review examined risk of cardiovascular events with vildagliptin, utilizing data from 25 RCTs; overall, no significant associations were found between vildagliptin and risk for cardiovascular events among both men and women.96

Bariatric surgery. Of 12 reviews on bariatric surgery, 2 examined sex effects on diabetes remission after bariatric surgery; both found no significant associations.100,101 Both reviews evaluated multiple types of bariatric surgery, included prospective and retrospective studies, and noted the generally low quality of included primary studies. One review included 39 studies, only 3 of which were RCTs; overall, diabetes remission rates varied significantly with the type of procedure (range 32.7% to 80.5% at 12 months) but not with age, sex, preoperative body mass index, or HbA1c.100 This review also examined adverse events and complications following bariatric surgery but did not report sex-specific analyses for these outcomes.100 The other review found 15 eligible studies and included data from 13 in meta-analyses evaluating the likelihood of diabetes remission; results showed decreased likelihood of remission with increasing age and diabetes duration but no significant associations with sex.101

In summary, sex effects were rarely examined, and reviews reporting sex results most often used meta-regression, a technique that is poorly suited to evaluating sex differences.103,104 All IPD meta-analyses examining sex effects were on incretin mimetics and there were no significant sex effects for any outcome. Using meta-regression, one review found greater improvement of insulin resistance following short-term intensive insulin therapy in trials with more women; however, this physiologic outcome is of unclear clinical significance. No sex effects were found for diabetes remission after bariatric surgery. Multiple features of diabetes self-management education may be associated with positive effects in minority women.

### Primary Studies: Reporting of Sex Effects for Diabetes Interventions

Reviews of dietary interventions,105 mixed behavioral interventions,106 and culturally tailored psychoeducation83 were selected for further analysis of a sample of primary studies (see Methods) because we did not identify any IPD meta-analyses for these high-priority interventions.

Six of the 20 primary studies (30%) evaluating dietary interventions randomized at least 75 patients to each treatment arm.107-112 Sample sizes in these studies ranged from 162 to 1224. One trial enrolled only women,109 and none enrolled Veterans. Two RCTs evaluated sex as a moderator, and neither found a differential response for effects on weight110 or HbA1c.108

Only 2 of 17 studies (12%) evaluating mixed behavioral interventions met the sample size requirement (n=182^113^ and n=606^114^). These studies enrolled mixed samples of men and women, and did not describe Veteran enrollment. One study evaluated sex effects and found a greater effect of physical activity on glycemic control in men.113

Thirty-three clinical RCTs evaluated culturally tailored psychoeducation, and of these, 11 (33%) met the sample size requirement.115-125 The number of patients randomized ranged from 201 to 567. Two RCTs enrolled only women,116,117 and none enrolled Veterans. One study evaluated sex effects and found no differential effect for HbA1c, fasting blood glucose, or diabetes knowledge.115

## CHRONIC PAIN

### Overview

Three pain conditions were prioritized for review: chronic low back pain (CLBP), fibromyalgia (FM), and chronic knee pain due to osteoarthritis (knee OA). CLBP was limited to musculoskeletal or mechanical low back pain to differentiate it from inflammatory conditions for which specific treatments would be indicated.

Sixty-eight systematic reviews evaluated interventions specifically for CLBP (n=26), FM (n=34), and knee OA (n=8); one review evaluated acupuncture for both CLBP and knee OA. The most frequently evaluated interventions were exercise (n=21), medications (antidepressant, n=9; anticonvulsant, n=6; joint injection, n=5; and topical nonsteroidal anti-inflammatory drug, n=3), acupuncture and chiropractic manipulation (n=12), behavioral treatment (n=8), and combination interventions (n=4). One review on CLBP evaluated quality improvement interventions.

The eligible reviews included from 2 to 102 primary studies, and all but 11 reviews restricted inclusion to RCTs. Sixteen reviews originated from an organization known for high-quality systematic reviews. Figure 6 shows a heat map of the number of primary studies evaluated in the largest review for each chronic pain condition–intervention dyad. Most reviews used quantitative meta-analyses to evaluate intervention effects. One review used IPD meta-analyses.

Figure 6 Number of primary studies included in largest review for each condition–intervention dyad

The percentage of women included in the primary studies was reported in 8 of 26 reviews on CLBP and ranged from 45% to 100%.126-133 For FM, the percentage of women included in the primary studies was reported in 23 of the 34 reviews on FM and ranged from 50% to 100% (median 95.5%). Five of 8 reviews of OA reported on the percentage of women, with the range being 50% to 100%.

### Systematic Reviews: Reporting of Sex Effects for Chronic Pain Interventions

Of the 68 systematic reviews, only 3 (4%) reported results about sex effects. Sex effects were discussed in 2 reviews of CLBP126,132 and one review of FM.134 All of these reviews explored sex effects using meta-regression. We describe below key findings from reviews reporting sex effects for CLBP interventions, as well as some general findings from FM reviews.

Chronic low back pain. No review examined sex effects as a primary aim in CLBP; however, 2 evaluated sex effects using meta-regression. In a review evaluating the effectiveness of antidepressants and other medications for pain, sex was not associated with differences in treatment effect.126 In a review examining quality improvement interventions, increasing proportion of women in the primary studies was associated with greater intervention effectiveness (beta=0.002; SE 0.001).132

Fibromyalgia. Only one review proposed to evaluate differential effects in men and women, but individual patient-level data were not available.134 Also, we anticipated that analyses for sex effects would be difficult and require very large sample sizes, given that generally, more than 90% of the study participants were women. However, since women were the overwhelming majority of participants in trials for FM, reviews without sex specific analyses remain highly applicable to women. For this reason, we briefly outline results from FM reviews below, with more detailed results provided in Appendix G.

Of 34 eligible reviews, 14 examined medications (n=7 for antidepressants,134-140 n=5 for anticonvulsant agents,137,141-144 and n=2 for both classes145,146). The largest review of antidepressants addressed the effectiveness of duloxetine and milnacipran, and included 10 studies; there were small improvements in pain (SMD -0.23, CI -0.29 to -0.18), and quality of life (SMD -0.20, CI of -0.25 to -0.14).134 Additional reviews that also evaluated these medications136,137 found similar results. Reviews on anticonvulsants (ie, gabapentin and pregabalin) also showed improvement in pain.137,141-144

Six reviews evaluated various forms of exercise,147-152 and while most of these showed some effectiveness for pain, there did not appear to be differences between different types of exercise (eg, aquatic vs land-based). Six reviews examined different types of psychotherapy or behavioral interventions.153-158 A recent large review of CBT found low-quality evidence to support a small improvement in pain symptoms with CBT.153 Five reviews examined acupoint stimulation/acupuncture159-163 and found varying results depending on the type of comparator; compared with sham acupuncture, acupuncture did not significantly reduce FM-related pain. Two reviews on meditative movement therapies (ie, yoga, tai chi, and qigong) produced conflicting results, and it remains unclear if these therapies are beneficial.149,151 One review examined chiropractic care and concluded that there was no significant difference between intervention and control groups.164

Knee OA. None of the 8 reviews for knee OA included plans for an analysis of sex effects either as a primary aim or as a subgroup analysis.165-172

### Primary Studies: Reporting of Sex Effects for Chronic Pain Interventions

Reviews of knee OA167 and behavioral interventions for CLBP173 were selected for further analysis of a sample of primary studies (see Methods) because we did not identify any IPD meta-analyses for these high-priority interventions.

Thirty RCTs evaluated behavioral interventions for CLBP, and of these, 7 (23%) met the sample size requirement.174-180 The number of patients randomized ranged from 161 to 409. No trials were limited to enrolling women and none reported on Veteran enrollment. None of the trials evaluated sex effects.

Eight of the 54 studies (15%) included in the review of exercise interventions for knee OA met the sample size requirement.181-188 Sample sizes in these studies ranged from 182 to 439. No trials enrolled only women and none enrolled Veterans. Only one trial evaluated sex as a moderator, stating that “both sexes … showed similar improvement in self-reported disability, pain and 6-minute walk distance.”182

## SUMMARY: REPORTING OF SEX EFFECTS ACROSS ALL CONDITIONS

In Table 3, we summarize the key findings, across all conditions evaluated, of systematic reviews that address differential treatment effects between men and women. Overall, sex effects were evaluated more frequently in systematic reviews for depressive disorders. When differential treatment effects were identified, the differences between men and women were typically small.

Table 3 Summary of sex effects identified in systematic reviews

Condition | Possible differences in treatment effects between men and women | Possible lack of differences in treatment effects between men and women
Depressive disorders (Page 9) | [underlined: Greater improvement in depressive symptoms] CBT, duloxetine^a^ SSRIs in older adults [underlined: More adverse effects on sexual dysfunction] Paroxetine | [underlined: Depressive symptoms] Antidepressants overall, quality improvement, self-help^a^ Combined antidepressant and psychotherapy for dysthymia [underlined: Adverse effects overall] Antidepressants
Diabetes (Page 12) | [underlined: Fracture risk] Lower for sulfonylureas (compared with thiazolidinediones) | [underlined: Glycemic control] Linagliptin^a^, vildagliptin^a^ [underlined: Weight loss] Bariatric surgery
Chronic pain b (Page 17) | [underlined: Greater improvement in CLBP] Quality improvement | [underlined: CLBP] Antidepressants

a Findings are from individual patient data meta-analysis.

b Fibromyalgia is not listed because studies predominantly enrolled women. Knee osteoarthritis is not listed because no reviews were identified.

Abbreviations: CBT=cognitive behavioral therapy; CLBP=chronic low back pain; SSRI=selective serotonin reuptake inhibitor