# REFERENCES

1 Yano EM, Hayes P, Wright S, et al. Integration of women veterans into VA quality improvement research efforts: what researchers need to know. J Gen Intern Med. Suppl 1. 2010;25:56-61. [pmid: 20077153].
2 Yano EM, Bastian LA, Bean-Mayberry B, et al. Using research to transform care for women veterans: advancing the research agenda and enhancing research-clinical partnerships. Womens Health Issues. 2011;21(4 Suppl):S73-83. [pmid: 21724148].
3 Frayne SM, Phibbs CS, Saechao F, et al. Sourcebook: Women Veterans in the Veterans Health Administration. Volume 3. Sociodemographics, Utilization, Costs of Care, and Health Profile. Women's Health Evaluation Initiative, Women's Health Services, Veterans Health Administration, Department of Veterans Affairs. Washington DC. February. 2014.
4 Frayne SM, Parker VA, Christiansen CL, et al. Health status among 28,000 women veterans. The VA Women's Health Program Evaluation Project. J Gen Intern Med. Suppl 3. 2006;21:S40-46. [pmid: 16637944].
5 Frayne SM, Yu W, Yano EM, et al. Gender and use of care: planning for tomorrow's Veterans Health Administration. J Womens Health (Larchmt). 2007;16(8):1188-1199. [pmid: 17937572].
6 Skinner K, Sullivan LM, Tripp TJ, et al. Comparing the health status of male and female veterans who use VA health care: results from the VA Women's Health Project. Women Health. 1999;29(4):17-33. [pmid: 10608667].
7 Turner C, Frayne S. Veteran's Health Initiative: Military Sexual Trauma. Washington DC. Department of Veterans Affairs Employee Education System and the Center for Women's Health. 2004. Available at: http://www.publichealth.va.gov/vethealthinitiative/sexual_trauma.asp. July 16, 2015.
8 Batuman F, Bean-Mayberry B, Goldzweig C, et al. VA Evidence-based Synthesis Program Reports. Health Effects of Military Service on Women Veterans. Washington (DC). Department of Veterans Affairs. 2011.
9 Kimerling R, Gima K, Smith MW, Street A, Frayne S. The Veterans Health Administration and military sexual trauma. Am J Public Health. 2007;97(12):2160-2166. [pmid: 17971558].
10 Pinn VW. Sex and gender factors in medical studies: implications for health and clinical practice. JAMA. 2003;289(4):397-400. [pmid: 12533102].
11 Melloni C, Berger JS, Wang TY, et al. Representation of women in randomized clinical trials of cardiovascular disease prevention. Circ Cardiovasc Qual Outcomes. 2010;3(2):135-142. [pmid: 20160159].
12 Foulkes MA. After inclusion, information and inference: reporting on clinical trials results after 15 years of monitoring inclusion of women. J Womens Health (Larchmt). 2011;20(6):829-836. [pmid: 21671773].
13 Geller SE, Adams MG, Carnes M. Adherence to Federal Guidelines for Reporting of Sex and Race/Ethnicity in Clinical Trials. J Womens Health (Larchmt). 2006;15(10):1123-1131. [pmid: 17199453].
14 Blauwet LA, Hayes SN, McManus D, Redberg RF, Walsh MN. Low rate of sex-specific result reporting in cardiovascular trials. Mayo Clin Proc. 2007;82(2):166-170. [pmid: 17290722].
15 Bailey KR. Reporting of sex-specific results: a statistician's perspective. Mayo Clin Proc. 2007;82(2):158. [pmid: 17290720].
16 Prins MH, Smits KM, Smits LJ. Methodologic ramifications of paying attention to sex and gender differences in clinical research. Gend Med. Suppl B. 2007;4:S106-110. [pmid: 18156096].
17 Anthony M, Berg MJ. Biologic and molecular mechanisms for sex differences in pharmacokinetics, pharmacodynamics, and pharmacogenetics: Part I. J Womens Health Gend Based Med. 2002;11(7):601-615. [pmid: 12396893].
18 Berlin JA, Ellenberg SS. Inclusion of women in clinical trials. BMC Med. 2009;7:56. [pmid: 19818115].
19 Yang Y, Carlin AS, Faustino PJ, et al. Participation of Women in Clinical Trials for New Drugs Approved by the Food and Drug Administration in 2000–2002. J Womens Health (Larchmt). 2009;18(3):303-310. [pmid: 19243271].
20 Ryan RE, Kaufman CA, Hill SJ. Building blocks for meta-synthesis: data integration tables for summarising, mapping, and synthesising evidence on interventions for communicating with health consumers. BMC Med Res Methodol. 2009;9:16. [pmid: 19261177].
21 Bragge P, Clavisi O, Turner T, Tavender E, Collie A, Gruen RL. The Global Evidence Mapping Initiative: scoping research in broad topic areas. BMC Med Res Methodol. 2011;11:92. [pmid: 21682870].
22 Arksey H. Scoping the field: services for carers of people with mental health problems. Health Soc Care Community. 2003;11(4):335-344. [pmid: 14629205].
23 Chang SM, Carey TS, Kato EU, Guise JM, Sanders GD. Identifying research needs for improving health care. Ann Intern Med. 2012;157(6):439-445. [pmid: 22847017].
24 Centers for Disease Control and Prevention. National Hospital Ambulatory Medical Care Survey. Available at: http://www.cdc.gov/nchs/ahcd/about_ahcd.htm. February 3, 2015.
25 Centers for Disease Control and Prevention. Arthritis Among Veterans—United States, 2011–2013. Available: http://www.cdc.gov/mmwr/preview/mmwrhtml/mm6344a4.htm. February 3, 2015.
26 Centers for Disease Control and Prevention. National Hospital Ambulatory Medical Care Survey Factsheet Outpatient Department. Available: http://www.cdc.gov/nchs/data/ahcd/NHAMCS_2010_opd_factsheet.pdf. Febuary 5, 2015. 2010.
27 Murphy SL, Xu J, Kochanek KD. Division of Vital Statistics, “Deaths: Final Data for 2010,” (Centers for Disease Control). Available: http://www.cdc.gov/nchs/data/nvsr/nvsr61/nvsr61_04.pdf. Febuary 5, 2015. 2013;61(4).
28 National Cancer Institute. Surveillance, Epidemiology, and End Results (SEER) Program. http://seer.cancer.gov/. Febuary 5 2015.
29 Shojania KG, Sampson M, Ansari MT, Ji J, Doucette S, Moher D. How quickly do systematic reviews go out of date? A survival analysis. Ann Intern Med. 2007;147(4):224-233. [pmid: 17638714].
30 Riley RD, Lambert PC, Abo-Zaid G. Meta-analysis of individual participant data: rationale, conduct, and reporting. BMJ. 2010;340:c221. [pmid: 20139215].
31 Leon AC, Heo M. Sample sizes required to detect interactions between two binary fixed-effects in a mixed-effects linear regression model. Comput Stat Data Anal. 2009;53(3):603-608. [pmid: 20084090].
32 Churchill R, Moore TH, Furukawa TA, et al. “Third wave” cognitive and behavioural therapies versus treatment as usual for depression. Cochrane Database Syst Rev. 2013;10. Cd008705.
33 Cuijpers P, van Straten A, Bohlmeijer E, Hollon SD, Andersson G. The effects of psychotherapy for adult depression are overestimated: a meta-analysis of study quality and effect size. Psychol Med. 2010;40(2):211-223. [pmid: 19490745].
34 Gartlehner G, Hansen RA, Morgan LC, et al. Comparative benefits and harms of second-generation antidepressants for treating major depressive disorder: an updated meta-analysis. Ann Intern Med. 2011;155(11):772-785. [pmid: 22147715].
35 Hunot V, Moore TH, Caldwell DM, et al. “Third wave” cognitive and behavioural therapies versus other psychological therapies for depression. Cochrane Database Syst Rev. 2013;10. Cd008704.
36 Nieuwsma JA, Trivedi RB, McDuffie J, Kronish I, Benjamin D, Williams JW. Brief psychotherapy for depression: a systematic review and meta-analysis. Int J Psychiatry Med. 2012;43(2):129-151. [pmid: 22849036].
37 Roshanaei-Moghaddam B, Pauly MC, Atkins DC, Baldwin SA, Stein MB, Roy-Byrne P. Relative effects of CBT and pharmacotherapy in depression versus anxiety: is medication somewhat better for depression, and CBT somewhat better for anxiety?. Depress Anxiety. 2011;28(7):560-567. [pmid: 21608087].
38 Shinohara K, Honyashiki M, Imai H, et al. Behavioural therapies versus other psychological therapies for depression. Cochrane Database Syst Rev. 2013;10. Cd008696.
39 Trivedi RB, Nieuwsma JA, Williams JW Jr. Examination of the utility of psychotherapy for patients with treatment resistant depression: a systematic review. J Gen Intern Med. 2011;26(6):643-650. [pmid: 21184287].
40 Rubenstein LV, Williams JW Jr., Danz M, Shekelle P, Suttorp M, Johnsen B. VA Evidence-based Synthesis Program Reports. Determining Key Features of Effective Depression Interventions. Washington (DC). Department of Veterans Affairs (US). 2009.
41 Bower P, Kontopantelis E, Sutton A, et al. Influence of initial severity of depression on effectiveness of low intensity interventions: meta-analysis of individual patient data. BMJ. 2013;346:f540. [pmid: 23444423].
42 Carpenter DJ, Fong R, Kraus JE, Davies JT, Moore C, Thase ME. Meta-analysis of efficacy and treatment-emergent suicidality in adults by psychiatric indication and age subgroup following initiation of paroxetine therapy: a complete set of randomized placebo-controlled trials. J Clin Psychiatry. 2011;72(11):1503-1514. [pmid: 21367354].
43 Fournier JC, DeRubeis RJ, Hollon SD, et al. Antidepressant drug effects and depression severity: a patient-level meta-analysis. JAMA. 2010;303(1):47-53. [pmid: 20051569].
44 Gibbons RD, Hur K, Brown CH, Davis JM, Mann JJ. Benefits from antidepressants: synthesis of 6-week patient-level outcomes from double-blind placebo-controlled randomized trials of fluoxetine and venlafaxine. Arch Gen Psychiatry. 2012;69(6):572-579. [pmid: 22393205].
45 Gibbons RD, Brown CH, Hur K, Davis J, Mann JJ. Suicidal thoughts and behavior with antidepressant treatment: reanalysis of the randomized placebo-controlled studies of fluoxetine and venlafaxine. Arch Gen Psychiatry. 2012;69(6):580-587. [pmid: 22309973].
46 Kasper S, Corruble E, Hale A, Lemoine P, Montgomery SA, Quera-Salva MA. Antidepressant efficacy of agomelatine versus SSRI/SNRI: results from a pooled analysis of head-to-head studies without a placebo control. Int Clin Psychopharmacol. 2013;28(1):12-19. [pmid: 23023074].
47 Kennedy SH, Andersen HF, Thase ME. Escitalopram in the treatment of major depressive disorder: a meta-analysis. (Structured abstract). Curr Med Res Opin. 2009;25(1):161-175. http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12009105228/frame.html. [pmid: 19210149].
48 Mancini M, Sheehan DV, Demyttenaere K, et al. Evaluation of the effect of duloxetine treatment on functioning as measured by the Sheehan disability scale: pooled analysis of data from six randomized, double-blind, placebo-controlled clinical studies. Int Clin Psychopharmacol. 2012;27(6):298-309. [pmid: 22954893].
49 Papakostas GI, Culpepper L, Fayyad RS, Musgnung J, Guico-Pabia CJ. Efficacy of desvenlafaxine 50 mg compared with placebo in patients with moderate or severe major depressive disorder: a pooled analysis of six randomized, double-blind, placebo-controlled studies. (Provisional abstract). Database of Abstracts of Reviews of Effects. 2013;(4):312-321. http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12013063325/frame.html.
50 Soares CN, Fayyad RS, Guico-Pabia CJ. Early improvement in depressive symptoms with desvenlafaxine 50 mg/d as a predictor of treatment success in patients with major depressive disorder. J Clin Psychopharmacol. 2014;34(1):57-65. [pmid: 24346751].
51 von Wolff A, Holzel LP, Westphal A, Harter M, Kriston L. Combination of pharmacotherapy and psychotherapy in the treatment of chronic depression: a systematic review and meta-analysis. BMC Psychiatry. 2012;12:61. [pmid: 22694751].
52 Braun SR, Gregor B, Tran US. Comparing bona fide psychotherapies of depression in adults with two meta-analytical approaches. PLoS One. 2013;8(6):e68135. [pmid: 23840824].
53 Driessen E, Cuijpers P, de Maat SC, Abbass AA, de Jonghe F, Dekker JJ. The efficacy of short-term psychodynamic psychotherapy for depression: a meta-analysis. Clin Psychol Rev. 2010;30(1):25-36. [pmid: 19766369].
54 Driessen E, Cuijpers P, Hollon SD, Dekker JJ. Does pretreatment severity moderate the efficacy of psychological treatment of adult outpatient depression? A meta-analysis. J Consult Clin Psychol. 2010;78(5):668-680. [pmid: 20873902].
55 Cuijpers P, Reynolds CF 3rd, Donker T, Li J, Andersson G, Beekman A. Personalized treatment of adult depression: medication, psychotherapy, or both? A systematic review. Depress Anxiety. 2012;29(10):855-864. [pmid: 22815247].
56 Calati R, Salvina Signorelli M, Balestri M, et al. Antidepressants in elderly: metaregression of double-blind, randomized clinical trials. J Affect Disord. 2013;147(1-3):1-8. [pmid: 23245467].
57 Carter GC, Cantrell RA, Victoria Z, et al. Comprehensive review of factors implicated in the heterogeneity of response in depression. Depress Anxiety. 2012;29(4):340-354. [pmid: 22511365].
58 Gibiino S, Marsano A, Serretti A. Specificity profile of venlafaxine and sertraline in major depression: metaregression of double-blind, randomized clinical trials. (Provisional abstract). International Journal of Neuropsychopharmacology. 2014;17(1):1-8. http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12014002430/frame.html. [pmid: 23953038].
59 Thota AB, Sipe TA, Byard GJ, et al. Collaborative care to improve the management of depressive disorders: a community guide systematic review and meta-analysis. Am J Prev Med. 2012;42(5):525-538. [pmid: 22516495].
60 Cuijpers P, Karyotaki E, Weitz E, Andersson G, Hollon SD, van Straten A. The effects of psychotherapies for major depression in adults on remission, recovery and improvement: a meta-analysis. J Affect Disord. 2014;159:118-126. [pmid: 24679399].
61 Araya R, Rojas G, Fritsch R, et al. Treating depression in primary care in low-income women in Santiago, Chile: a randomised controlled trial. Lancet. 2003;361(9362):995-1000. [pmid: 12660056].
62 Fortney JC, Pyne JM, Edlund MJ, et al. A randomized trial of telemedicine-based collaborative care for depression. J Gen Intern Med. 2007;22(8):1086-1093. [pmid: 17492326].
63 Hedrick SC, Chaney EF, Felker B, et al. Effectiveness of collaborative care depression treatment in Veterans' Affairs primary care. J Gen Intern Med. 2003;18(1):9-16. [pmid: 12534758].
64 Swindle RW, Rao JK, Helmy A, et al. Integrating clinical nurse specialists into the treatment of primary care patients with depression. Int J Psychiatry Med. 2003;33(1):17-37. [pmid: 12906341].
65 Unutzer J, Katon W, Callahan CM, et al. Collaborative care management of late-life depression in the primary care setting: a randomized controlled trial. JAMA. 2002;288(22):2836-2845. [pmid: 12472325].
66 Dobscha SK, Corson K, Hickam DH, Perrin NA, Kraemer DF, Gerrity MS. Depression decision support in primary care: a cluster randomized trial. Ann Intern Med. 2006;145(7):477-487. [pmid: 17015865].
67 Mann AH, Blizard R, Murray J, et al. An evaluation of practice nurses working with general practitioners to treat people with depression. Br J Gen Pract. 1998;48(426):875-879. [pmid: 9604408].
68 Simon GE, Ludman EJ, Tutty S, Operskalski B, Von Korff M. Telephone psychotherapy and telephone care management for primary care patients starting antidepressant treatment: a randomized controlled trial. JAMA. 2004;292(8):935-942. [pmid: 15328325].
69 Miranda J, Chung JY, Green BL, et al. Treating depression in predominantly low-income young minority women: a randomized controlled trial. JAMA. 2003;290(1):57-65. [pmid: 12837712].
70 Rahman A, Malik A, Sikander S, Roberts C, Creed F. Cognitive behaviour therapy-based intervention by community health workers for mothers with depression and their infants in rural Pakistan: a cluster-randomised controlled trial. Lancet. 2008;372(9642):902-909. [pmid: 18790313].
71 Frank E, Cassano GB, Rucci P, et al. Predictors and moderators of time to remission of major depression with interpersonal psychotherapy and SSRI pharmacotherapy. Psychol Med. 2011;41(1):151-162. [pmid: 20380782].
72 Bennett WL, Maruthur NM, Singh S, et al. Comparative effectiveness and safety of medications for type 2 diabetes: an update including new drugs and 2-drug combinations. Ann Intern Med. 2011;154(9):602-613. [pmid: 21403054].
73 Cleveringa FG, Gorter KJ, van den Donk M, van Gijsel J, Rutten GE. Computerized decision support systems in primary care for type 2 diabetes patients only improve patients' outcomes when combined with feedback on performance and case management: a systematic review. Diabetes Technol Ther. 2013;15(2):180-192. [pmid: 23360424].
74 Cramer H, Lauche R, Haller H, Steckhan N, Michalsen A, Dobos G. Effects of yoga on cardiovascular disease risk factors: a systematic review and meta-analysis. Int J Cardiol. 2014;173(2):170-183. [pmid: 24636547].
75 Egginton JS, Ridgeway JL, Shah ND, et al. Care management for Type 2 diabetes in the United States: a systematic review and meta-analysis. BMC Health Serv Res. 2012;12:72. [pmid: 22439920].
76 Hemmingsen B, Schroll JB, Lund SS, et al. Sulphonylurea monotherapy for patients with type 2 diabetes mellitus. Cochrane Database Syst Rev. 2013;4. Cd009008.
77 Lee NJ, Norris SL, Thakurta S. Efficacy and harms of the hypoglycemic agent pramlintide in diabetes mellitus. Ann Fam Med. 2010;8(6):542-549. [pmid: 21060125].
78 Salpeter SR, Greyber E, Pasternak GA, Salpeter Posthumous EE. Risk of fatal and nonfatal lactic acidosis with metformin use in type 2 diabetes mellitus. Cochrane Database Syst Rev. 2010;(1). Cd002967.
79 Schellenberg ES, Dryden DM, Vandermeer B, Ha C, Korownyk C. Lifestyle interventions for patients with and at risk for type 2 diabetes: a systematic review and meta-analysis. Ann Intern Med. 2013;159(8):543-551. [pmid: 24126648].
80 Shyangdan DS, Royle P, Clar C, Sharma P, Waugh N, Snaith A. Glucagon-like peptide analogues for type 2 diabetes mellitus. Cochrane Database Syst Rev. 2011;(10). Cd006423.
81 Sumamo E, Ha C, Korownyk C, Vandermeer B, Dryden DM. AHRQ Technology Assessments. Lifestyle Interventions for Four Conditions: Type 2 Diabetes, Metabolic Syndrome, Breast Cancer, and Prostate Cancer. Rockville (MD). Agency for Healthcare Research and Quality (US). 2011.
82 Tieu J, Coat S, Hague W, Middleton P. Oral anti-diabetic agents for women with pre-existing diabetes mellitus/impaired glucose tolerance or previous gestational diabetes mellitus. Cochrane Database of Systematic Reviews. 2010;(10). http://onlinelibrary.wiley.com/doi/10.1002/14651858.CD007724.pub2/abstract.
83 Attridge M, Creamer J, Ramsden M, Cannings-John R, Hawthorne K. Culturally appropriate health education for people in ethnic minority groups with type 2 diabetes mellitus. Cochrane Database of Systematic Reviews. 2014;(9). http://onlinelibrary.wiley.com/doi/10.1002/14651858.CD006424.pub3/abstract.
84 Bosetti C, Rosato V, Buniato D, Zambon A, La Vecchia C, Corrao G. Cancer risk for patients using thiazolidinediones for type 2 diabetes: a meta-analysis. Oncologist. 2013;18(2):148-156. [pmid: 23345544].
85 Col NF, Ochs L, Springmann V, Aragaki AK, Chlebowski RT. Metformin and breast cancer risk: a meta-analysis and critical literature review. Breast Cancer Res Treat. 2012;135(3):639-646. [pmid: 22847511].
86 Colmers IN, Bowker SL, Tjosvold LA, Johnson JA. Insulin use and cancer risk in patients with type 2 diabetes: a systematic review and meta-analysis of observational studies. Diabetes Metab. 2012;38(6):485-506. [pmid: 23159131].
87 Decensi A, Puntoni M, Goodwin P, et al. Metformin and cancer risk in diabetic patients: a systematic review and meta-analysis. Cancer Prev Res (Phila). 2010;3(11):1451-1461. [pmid: 20947488].
88 Franciosi M, Lucisano G, Lapice E, Strippoli GF, Pellegrini F, Nicolucci A. Metformin therapy and risk of cancer in patients with type 2 diabetes: systematic review. PLoS One. 2013;8(8):e71583. [pmid: 23936520].
89 Soranna D, Scotti L, Zambon A, et al. Cancer risk associated with use of metformin and sulfonylurea in type 2 diabetes: a meta-analysis. Oncologist. 2012;17(6):813-822. [pmid: 22643536].
90 Esposito K, Chiodini P, Bellastella G, Maiorino MI, Giugliano D. Proportion of patients at HbA1c target <7% with eight classes of antidiabetic drugs in type 2 diabetes: systematic review of 218 randomized controlled trials with 78 945 patients. Diabetes Obes Metab. 2012;14(3):228-233. [pmid: 21958121].
91 Groop PH, Del Prato S, Taskinen MR, et al. Linagliptin treatment in subjects with type 2 diabetes with and without mild-to-moderate renal impairment. Diabetes Obes Metab. 2014;16(6):560-568. [pmid: 24612167].
92 He S, Tang YH, Zhao G, Yang X, Wang D, Zhang Y. Pioglitazone prescription increases risk of bladder cancer in patients with type 2 diabetes: an updated meta-analysis. Tumour Biol. 2014;35(3):2095-2102. [pmid: 24092576].
93 Kramer CK, Zinman B, Retnakaran R. Short-term intensive insulin therapy in type 2 diabetes mellitus: a systematic review and meta-analysis. Lancet Diabetes Endocrinol. 2013;1(1):28-34. [pmid: 24622264].
94 Lamanna C, Monami M, Marchionni N, Mannucci E. Effect of metformin on cardiovascular events and mortality: a meta-analysis of randomized clinical trials. Diabetes Obes Metab. 2011;13(3):221-228. [pmid: 21205121].
95 Lapane KL, Yang S, Brown MJ, Jawahar R, Pagliasotti C, Rajpathak S. Sulfonylureas and risk of falls and fractures: a systematic review. Drugs Aging. 2013;30(7):527-547. [pmid: 23609875].
96 Schweizer A, Dejager S, Foley JE, Couturier A, Ligueros-Saylan M, Kothny W. Assessing the cardio-cerebrovascular safety of vildagliptin: meta-analysis of adjudicated events from a large Phase III type 2 diabetes population. Diabetes Obes Metab. 2010;12(6):485-494. [pmid: 20518804].
97 Johansen OE, Neubacher D, von Eynatten M, Patel S, Woerle HJ. Cardiovascular safety with linagliptin in patients with type 2 diabetes mellitus: a pre-specified, prospective, and adjudicated meta-analysis of a phase 3 programme. Cardiovasc Diabetol. 2012;11:3. [pmid: 22234149].
98 Esposito K, Cozzolino D, Bellastella G, et al. Dipeptidyl peptidase-4 inhibitors and HbA1c target of <7% in type 2 diabetes: meta-analysis of randomized controlled trials. Diabetes Obes Metab. 2011;13(7):594-603. [pmid: 21320267].
99 Fakhoury WK, Lereun C, Wright D. A meta-analysis of placebo-controlled clinical trials assessing the efficacy and safety of incretin-based medications in patients with type 2 diabetes. Pharmacology. 2010;86(1):44-57. [pmid: 20616619].
100 Parikh M, Issa R, Vieira D, et al. Role of bariatric surgery as treatment for type 2 diabetes in patients who do not meet current NIH criteria: a systematic review and meta-analysis. J Am Coll Surg. 2013;217(3):527-532. [pmid: 23890843].
101 Wang GF, Yan YX, Xu N, et al. Predictive Factors of Type 2 Diabetes Mellitus Remission Following Bariatric Surgery: a Meta-analysis. Obes Surg. 2015;25(2):199-208. [pmid: 25103403].
102 Gucciardi E, Chan VW, Manuel L, Sidani S. A systematic literature review of diabetes self-management education features to improve diabetes education in women of Black African/Caribbean and Hispanic/Latin American ethnicity. Patient Educ Couns. 2013;92(2):235-245. [pmid: 23566428].
103 Chapter 9: Analysing data and undertaking meta-analyses. Deeks Jonathan J, Higgins Julian PT, Altman Douglas G, on behalf of the Cochrane Statistical Methods Group, editors. Available at: http://handbook.cochrane.org/chapter_9/9_analysing_data_and_undertaking_meta_analyses.htm. July 31, 2015.
104 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. Available at: http://www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=318. July 16, 2015.
105 Ajala O, English P, Pinkney J. Systematic review and meta-analysis of different dietary approaches to the management of type 2 diabetes. Am J Clin Nutr. 2013;97(3):505-516. [pmid: 23364002].
106 Avery L, Flynn D, van Wersch A, Sniehotta FF, Trenell MI. Changing physical activity behavior in type 2 diabetes: a systematic review and meta-analysis of behavioral interventions. Diabetes Care. 2012;35(12):2681-2689. [pmid: 23173137].
107 Salas-Salvado J, Fernandez-Ballart J, Ros E, et al. Effect of a Mediterranean diet supplemented with nuts on metabolic syndrome status: one-year results of the PREDIMED randomized trial. Arch Intern Med. 2008;168(22):2449-2458. [pmid: 19064829].
108 Jenkins DJ, Kendall CW, McKeown-Eyssen G, et al. Effect of a low-glycemic index or a high-cereal fiber diet on type 2 diabetes: a randomized trial. JAMA. 2008;300(23):2742-2753. [pmid: 19088352].
109 Toobert DJ, Glasgow RE, Strycker LA, et al. Biologic and quality-of-life outcomes from the Mediterranean Lifestyle Program: a randomized clinical trial. Diabetes Care. 2003;26(8):2288-2293. [pmid: 12882850].
110 Esposito K, Maiorino MI, Ciotola M, et al. Effects of a Mediterranean-style diet on the need for antihyperglycemic drug therapy in patients with newly diagnosed type 2 diabetes: a randomized trial. Ann Intern Med. 2009;151(5):306-314. [pmid: 19721018].
111 Elhayany A, Lustman A, Abel R, Attal-Singer J, Vinker S. A low carbohydrate Mediterranean diet improves cardiovascular risk factors and diabetes control among overweight patients with type 2 diabetes mellitus: a 1-year prospective randomized intervention study. Diabetes Obes Metab. 2010;12(3):204-209. [pmid: 20151996].
112 Wolever TM, Gibbs AL, Mehling C, et al. The Canadian Trial of Carbohydrates in Diabetes (CCD), a 1-y controlled trial of low-glycemic-index dietary carbohydrate in type 2 diabetes: no effect on glycated hemoglobin but reduction in C-reactive protein. Am J Clin Nutr. 2008;87(1):114-125. [pmid: 18175744].
113 Balducci S, Zanuso S, Nicolucci A, et al. Effect of an intensive exercise intervention strategy on modifiable cardiovascular risk factors in subjects with type 2 diabetes mellitus: a randomized controlled trial: the Italian Diabetes and Exercise Study (IDES). Arch Intern Med. 2010;170(20):1794-1803. [pmid: 21059972].
114 Di Loreto C, Fanelli C, Lucidi P, et al. Validation of a counseling strategy to promote the adoption and the maintenance of physical activity by type 2 diabetic subjects. Diabetes Care. 2003;26(2):404-408. [pmid: 12547870].
115 Brown SA, Garcia AA, Kouzekanani K, Hanis CL. Culturally competent diabetes self-management education for Mexican Americans: the Starr County border health initiative. Diabetes Care. 2002;25(2):259-268. [pmid: 11815493].
116 Toobert DJ, Strycker LA, Barrera M Jr., Osuna D, King DK, Glasgow RE. Outcomes from a multiple risk factor diabetes self-management trial for Latinas. Ann Behav Med. 2011;41(3):310-323. [pmid: 21213091].
117 Toobert DJ, Strycker LA, King DK, Barrera M Jr., Osuna D, Glasgow RE. Long-term outcomes from a multiple-risk-factor diabetes trial for Latinas. Transl Behav Med. 2011;1(3):416-426. [pmid: 22022345].
118 Hawthorne K, Tomlinson S. One-to-one teaching with pictures--flashcard health education for British Asians with diabetes. Br J Gen Pract. 1997;47(418):301-304. [pmid: 9219407].
119 Lorig K, Ritter PL, Villa F, Piette JD. Spanish diabetes self-management with and without automated telephone reinforcement: two randomized trials. Diabetes Care. 2008;31(3):408-414. [pmid: 18096810].
120 O'Hare JP, Raymond NT, Mughal S, et al. Evaluation of delivery of enhanced diabetes care to patients of South Asian ethnicity: the United Kingdom Asian Diabetes Study (UKADS). Diabet Med. 2004;21(12):1357-1365. [pmid: 15569141].
121 Rosal MC, Ockene IS, Restrepo A, et al. Randomized trial of a literacy-sensitive, culturally tailored diabetes self-management intervention for low-income latinos: latinos en control. Diabetes Care. 2011;34(4):838-844. [pmid: 21378213].
122 Crowley MJ, Powers BJ, Olsen MK, et al. The Cholesterol, Hypertension, And Glucose Education (CHANGE) study: results from a randomized controlled trial in African Americans with diabetes. Am Heart J. 2013;166(1):179-186. [pmid: 23816038].
123 Anderson RM, Funnell MM, Nwankwo R, Gillard ML, Oh M, Fitzgerald JT. Evaluating a problem-based empowerment program for African Americans with diabetes: results of a randomized controlled trial. Ethn Dis. 2005;15(4):671-678. [pmid: 16259492].
124 Bellary S, O'Hare JP, Raymond NT, et al. Enhanced diabetes care to patients of south Asian ethnic origin (the United Kingdom Asian Diabetes Study): a cluster randomised controlled trial. Lancet. 2008;371(9626):1769-1776. [pmid: 18502301].
125 Gary TL, Batts-Turner M, Yeh HC, et al. The effects of a nurse case manager and a community health worker team on diabetic control, emergency department visits, and hospitalizations among urban African Americans with type 2 diabetes mellitus: a randomized controlled trial. Arch Intern Med. 2009;169(19):1788-1794. [pmid: 19858437].
126 Cawston H, Davie A, Paget MA, Skljarevski V, Happich M. Efficacy of duloxetine versus alternative oral therapies: an indirect comparison of randomised clinical trials in chronic low back pain. Eur Spine J. 2013;22(9):1996-2009. [pmid: 23686477].
127 Cramer H, Lauche R, Haller H, Dobos G. A systematic review and meta-analysis of yoga for low back pain. Clin J Pain. 2013;29(5):450-460. [pmid: 23246998].
128 Holtzman S, Beggs RT. Yoga for chronic low back pain: a meta-analysis of randomized controlled trials. Pain Res Manag. 2013;18(5):267-272. [pmid: 23894731].
129 Lam M, Galvin R, Curry P. Effectiveness of acupuncture for nonspecific chronic low back pain: a systematic review and meta-analysis. Spine (Phila Pa 1976). 2013;38(24):2124-2138. [pmid: 24026151].
130 Meng XG, Yue SW. Efficacy of Aerobic Exercise for Treatment of Chronic Low Back Pain: A Meta-Analysis. Am J Phys Med Rehabil. 2014.
131 Ward L, Stebbings S, Cherkin D, Baxter GD. Yoga for functional ability, pain and psychosocial outcomes in musculoskeletal conditions: a systematic review and meta-analysis. Musculoskeletal Care. 2013;11(4):203-217. [pmid: 23300142].
132 Waterschoot FP, Dijkstra PU, Hollak N, de Vries HJ, Geertzen JH, Reneman MF. Dose or content? Effectiveness of pain rehabilitation programs for patients with chronic low back pain: a systematic review. Pain. 2014;155(1):179-189. [pmid: 24135435].
133 Wells C, Kolt GS, Marshall P, Hill B, Bialocerkowski A. The effectiveness of Pilates exercise in people with chronic low back pain: a systematic review. PLoS One. 2014;9(7):e100402. [pmid: 24984069].
134 Hauser W, Urrutia G, Tort S, Uceyler N, Walitt B. Serotonin and noradrenaline reuptake inhibitors (SNRIs) for fibromyalgia syndrome. Cochrane Database Syst Rev. 2013;1. Cd010292.
135 Moore RA, Derry S, Aldington D, Cole P, Wiffen PJ. Amitriptyline for neuropathic pain and fibromyalgia in adults. Cochrane Database Syst Rev. 2012;12. Cd008242.
136 Lunn MP, Hughes RA, Wiffen PJ. Duloxetine for treating painful neuropathy, chronic pain or fibromyalgia. Cochrane Database Syst Rev. 2014;1. Cd007115.
137 Derry S, Gill D, Phillips T, Moore RA. Milnacipran for neuropathic pain and fibromyalgia in adults. Cochrane Database Syst Rev. 2012;3. Cd008244.
138 Choy E, Marshall D, Gabriel ZL, Mitchell SA, Gylee E, Dakin HA. A systematic review and mixed treatment comparison of the efficacy of pharmacological treatments for fibromyalgia. Semin Arthritis Rheum. 2011;41(3):335-345.e336. [pmid: 21868065].
139 Hauser W, Wolfe F, Tolle T, Uceyler N, Sommer C. The role of antidepressants in the management of fibromyalgia syndrome: a systematic review and meta-analysis. CNS Drugs. 2012;26(4):297-307. [pmid: 22452526].
140 Hauser W, Petzke F, Uceyler N, Sommer C. Comparative efficacy and acceptability of amitriptyline, duloxetine and milnacipran in fibromyalgia syndrome: a systematic review with meta-analysis. Rheumatology (Oxford). 2011;50(3):532-543. [pmid: 21078630].
141 Uceyler N, Sommer C, Walitt B, Hauser W. Anticonvulsants for fibromyalgia. Cochrane Database Syst Rev. 2013;10. Cd010782.
142 Straube S, Derry S, Moore RA, McQuay HJ. Pregabalin in fibromyalgia: meta-analysis of efficacy and safety from company clinical trial reports. Rheumatology (Oxford). 2010;49(4):706-715. [pmid: 20056767].
143 Tzellos TG, Toulis KA, Goulis DG, et al. Gabapentin and pregabalin in the treatment of fibromyalgia: a systematic review and a meta-analysis. J Clin Pharm Ther. 2010;35(6):639-656. [pmid: 21054455].
144 Moore RA, Straube S, Wiffen Philip J, Derry S, McQuay Henry J. Pregabalin for acute and chronic pain in adults. Cochrane Database of Systematic Reviews. 2009;(3). http://onlinelibrary.wiley.com/doi/10.1002/14651858.CD007076.pub2/abstract.
145 Hauser W, Petzke F, Sommer C. Comparative efficacy and harms of duloxetine, milnacipran, and pregabalin in fibromyalgia syndrome. J Pain. 2010;11(6):505-521. [pmid: 20418173].
146 Roskell NS, Beard SM, Zhao Y, Le TK. A meta-analysis of pain response in the treatment of fibromyalgia. Pain Pract. 2011;11(6):516-527. [pmid: 21199320].
147 Bidonde J, Busch AJ, Webber SC, et al. Aquatic exercise training for fibromyalgia. Cochrane Database Syst Rev. 2014;10. Cd011336.
148 Hauser W, Klose P, Langhorst J, et al. Efficacy of different types of aerobic exercise in fibromyalgia syndrome: a systematic review and meta-analysis of randomised controlled trials. Arthritis Res Ther. 2010;12(3):R79. [pmid: 20459730].
149 Langhorst J, Klose P, Dobos GJ, Bernardy K, Hauser W. Efficacy and safety of meditative movement therapies in fibromyalgia syndrome: a systematic review and meta-analysis of randomized controlled trials. Rheumatol Int. 2013;33(1):193-207. [pmid: 22350253].
150 Busch AJ, Webber SC, Richards RS, et al. Resistance exercise training for fibromyalgia. Cochrane Database Syst Rev. 2013;12. Cd010884.
151 Mist SD, Firestone KA, Jones KD. Complementary and alternative exercise for fibromyalgia: a meta-analysis. J Pain Res. 2013;6:247-260. [pmid: 23569397].
152 Lima TB, Dias JM, Mazuquin BF, et al. The effectiveness of aquatic physical therapy in the treatment of fibromyalgia: a systematic review with meta-analysis. Clin Rehabil. 2013;27(10):892-908. [pmid: 23818412].
153 Bernardy K, Klose P, Busch AJ, Choy EH, Hauser W. Cognitive behavioural therapies for fibromyalgia. Cochrane Database Syst Rev. 2013;9. Cd009796.
154 Bernardy K, Fuber N, Kollner V, Hauser W. Efficacy of cognitive-behavioral therapies in fibromyalgia syndrome - a systematic review and metaanalysis of randomized controlled trials. J Rheumatol. 2010;37(10):1991-2005. [pmid: 20682676].
155 Lauche R, Cramer H, Dobos G, Langhorst J, Schmidt S. A systematic review and meta-analysis of mindfulness-based stress reduction for the fibromyalgia syndrome. J Psychosom Res. 2013;75(6):500-510. [pmid: 24290038].
156 Veehof MM, Oskam MJ, Schreurs KM, Bohlmeijer ET. Acceptance-based interventions for the treatment of chronic pain: a systematic review and meta-analysis. Pain. 2011;152(3):533-542. [pmid: 21251756].
157 Glombiewski JA, Bernardy K, Hauser W. Efficacy of EMG- and EEG-Biofeedback in Fibromyalgia Syndrome: A Meta-Analysis and a Systematic Review of Randomized Controlled Trials. Evid Based Complement Alternat Med. 2013;2013:962741. [pmid: 24082911].
158 Glombiewski JA, Sawyer AT, Gutermann J, Koenig K, Rief W, Hofmann SG. Psychological treatments for fibromyalgia: a meta-analysis. Pain. 2010;151(2):280-295. [pmid: 20727679].
159 Yang B, Yi G, Hong W, et al. Efficacy of acupuncture on fibromyalgia syndrome: a meta-analysis. J Tradit Chin Med. 2014;34(4):381-391. [pmid: 25185355].
160 Cao H, Li X, Han M, Liu J. Acupoint stimulation for fibromyalgia: a systematic review of randomized controlled trials. Evid Based Complement Alternat Med. 2013;2013:362831. [pmid: 24454493].
161 Deare JC, Zheng Z, Xue CC, et al. Acupuncture for treating fibromyalgia. Cochrane Database Syst Rev. 2013;5. Cd007070.
162 Cao H, Liu J, Lewith GT. Traditional Chinese Medicine for treatment of fibromyalgia: a systematic review of randomized controlled trials. J Altern Complement Med. 2010;16(4):397-409. [pmid: 20423209].
163 Langhorst J, Klose P, Musial F, Irnich D, Hauser W. Efficacy of acupuncture in fibromyalgia syndrome--a systematic review with a meta-analysis of controlled clinical trials. Rheumatology (Oxford). 2010;49(4):778-788. [pmid: 20100789].
164 Ernst E. Chiropractic treatment for fibromyalgia: a systematic review. Clin Rheumatol. 2009;28(10):1175-1178. [pmid: 19544042].
165 Bannuru RR, Natov NS, Dasi UR, Schmid CH, McAlindon TE. Therapeutic trajectory following intra-articular hyaluronic acid injection in knee osteoarthritis--meta-analysis. Osteoarthritis Cartilage. 2011;19(6):611-619. [pmid: 21443958].
166 Derry S, Moore RA, Rabbie R. Topical NSAIDs for chronic musculoskeletal pain in adults. Cochrane Database Syst Rev. 2012;9. Cd007400.
167 Fransen M, McConnell S, Harmer AR, Van der Esch M, Simic M, Bennell KL. Exercise for osteoarthritis of the knee. Cochrane Database Syst Rev. 2015;1. Cd004376.
168 Vickers AJ, Cronin AM, Maschino AC, et al. Acupuncture for chronic pain: individual patient data meta-analysis. Arch Intern Med. 2012;172(19):1444-1453. [pmid: 22965186].
169 Avouac J, Vicaut E, Bardin T, Richette P. Efficacy of joint lavage in knee osteoarthritis: meta-analysis of randomized controlled studies. Rheumatology. (Oxford). 2010;49(2):334-340. [pmid: 19955221].
170 Wallis JA, Taylor NF. Pre-operative interventions (non-surgical and non-pharmacological) for patients with hip or knee osteoarthritis awaiting joint replacement surgery--a systematic review and meta-analysis. Osteoarthritis Cartilage. 2011;19(12):1381-1395. [pmid: 21959097].
171 Smith TO, King JJ, Hing CB. The effectiveness of proprioceptive-based exercise for osteoarthritis of the knee: a systematic review and meta-analysis. Rheumatol Int. 2012;32(11):3339-3351. [pmid: 22821333].
172 Khoshbin A, Leroux T, Wasserstein D, et al. The efficacy of platelet-rich plasma in the treatment of symptomatic knee osteoarthritis: a systematic review with quantitative synthesis. Arthroscopy. 2013;29(12):2037-2048. [pmid: 24286802].
173 Henschke N, Ostelo RW, van Tulder MW, et al. Behavioural treatment for chronic low-back pain. Cochrane Database Syst Rev. 2010;(7). Cd002014.
174 Fairbank J, Frost H, Wilson-MacDonald J, Yu LM, Barker K, Collins R. Randomised controlled trial to compare surgical stabilisation of the lumbar spine with an intensive rehabilitation programme for patients with chronic low back pain: the MRC spine stabilisation trial. Bmj. 2005;330(7502):1233. [pmid: 15911537].
175 Johnson RE, Jones GT, Wiles NJ, et al. Active exercise, education, and cognitive behavioral therapy for persistent disabling low back pain: a randomized controlled trial. Spine (Phila Pa 1976). 2007;32(15):1578-1585. [pmid: 17621203].
176 Poole H, Glenn S, Murphy P. A randomised controlled study of reflexology for the management of chronic low back pain. Eur J Pain. 2007;11(8):878-887. [pmid: 17459741].
177 Rose MJ, Reilly JP, Pennie B, Bowen-Jones K, Stanley IM, Slade PD. Chronic low back pain rehabilitation programs: a study of the optimum duration of treatment and a comparison of group and individual therapy. Spine (Phila Pa 1976). 1997;22(19):2246-2251. discussion 2252-2243. [pmid: 9346145].
178 Schweikert B, Jacobi E, Seitz R, et al. Effectiveness and cost-effectiveness of adding a cognitive behavioral treatment to the rehabilitation of chronic low back pain. J Rheumatol. 2006;33(12):2519-2526. [pmid: 17143986].
179 Smeets RJ, Vlaeyen JW, Hidding A, Kester AD, van der Heijden GJ, Knottnerus JA. Chronic low back pain: physical training, graded activity with problem solving training, or both? The one-year post-treatment results of a randomized controlled trial. Pain. 2008;134(3):263-276. [pmid: 17498879].
180 Von Korff M, Balderson BH, Saunders K, et al. A trial of an activating intervention for chronic back pain in primary care and physical therapy settings. Pain. 2005;113(3):323-330. [pmid: 15661440].
181 Hay EM, Foster NE, Thomas E, et al. Effectiveness of community physiotherapy and enhanced pharmacy review for knee pain in people aged over 55 presenting to primary care: pragmatic randomised trial. Bmj. 2006;333(7576):995. [pmid: 17056608].
182 Ettinger WH Jr., Burns R, Messier SP, et al. A randomized trial comparing aerobic exercise and resistance exercise with a health education program in older adults with knee osteoarthritis. The Fitness Arthritis and Seniors Trial (FAST). JAMA. 1997;277(1):25-31. [pmid: 8980206].
183 Kao MJ, Wu MP, Tsai MW, Chang WW, Wu SF. The effectiveness of a self-management program on quality of life for knee osteoarthritis (OA) patients. Arch Gerontol Geriatr. 2012;54(2):317-324. [pmid: 21726907].
184 Hurley MV, Walsh NE, Mitchell HL, et al. Clinical effectiveness of a rehabilitation program integrating exercise, self-management, and active coping strategies for chronic knee pain: a cluster randomized trial. Arthritis Rheum. 2007;57(7):1211-1219. [pmid: 17907147].
185 Jenkinson CM, Doherty M, Avery AJ, et al. Effects of dietary intervention and quadriceps strengthening exercises on pain and function in overweight people with knee pain: randomised controlled trial. Bmj. 2009;339:b3170. [pmid: 19690345].
186 Messier SP, Loeser RF, Miller GD, et al. Exercise and dietary weight loss in overweight and obese older adults with knee osteoarthritis: the Arthritis, Diet, and Activity Promotion Trial. Arthritis Rheum. 2004;50(5):1501-1510. [pmid: 15146420].
187 O'Reilly SC, Muir KR, Doherty M. Effectiveness of home exercise on pain and disability from osteoarthritis of the knee: a randomised controlled trial. Ann Rheum Dis. 1999;58(1):15-19. [pmid: 10343535].
188 Yip YB, Sit JW, Fung KK, et al. Impact of an Arthritis Self-Management Programme with an added exercise component for osteoarthritic knee sufferers on improving pain, functional outcomes, and use of health care services: An experimental study. Patient Educ Couns. 2007;65(1):113-121. [pmid: 17010554].
189 Kim ESH, Carrigan TP, Menon V. Enrollment of Women in National Heart, Lung, and Blood Institute-Funded Cardiovascular Randomized Controlled Trials Fails to Meet Current Federal Mandates for Inclusion. J Am Coll Cardiol. 2008;52(8):672-673. [pmid: 18702973].
190 Johnson SM, Karvonen CA, Phelps CL, Nader S, Sanborn BM. Assessment of analysis by gender in the Cochrane reviews as related to treatment of cardiovascular disease. J Womens Health (Larchmt). 2003;12(5):449-457. [pmid: 12869292].
191 National Institutes of Health. NIH Policy and Guidelines on the Inclusion of Women and Minorities as Subjects in Clinical Research – Amended, October, 2001. Available at: http://grants.nih.gov/grants/funding/women_min/guidelines_amended_10_2001.htm. July 27, 2015.
192 Clayton JA, Collins FS. Policy: NIH to balance sex in cell and animal studies. Nature. 2014;509(7500):282-283. [pmid: 24834516].
193 Farkas RH, Unger EF, Temple R. Zolpidem and driving impairment—identifying persons at risk. N Engl J Med. 2013;369(8):689-691. [pmid: 23923991].
194 National Institutes of Health, NIH Office of Research on Women's Health. Inclusion of Women and Minorities in Clinical Research. Available at: http://orwh.od.nih.gov/research/inclusion/index.asp. July 27, 2015.
195 Frayne SM, Carney DV, Bastian L, et al. The VA Women's Health Practice-Based Research Network: amplifying women veterans' voices in VA research. J Gen Intern Med. Suppl 2. 2013;28:S504-509. [pmid: 23807057].
196 Yano EM. A partnered research initiative to accelerate implementation of comprehensive care for women veterans: the VA women's health CREATE. Med Care. 2015;53(4 Suppl 1):S10-14. [pmid: 25767962].
197 Hudson KL, Collins FS. Sharing and reporting the results of clinical trials. JAMA. 2015;313(4):355-356. [pmid: 25408371].
198 Kokras N, Dalla C, Papadopoulou-Daifoti Z. Sex differences in pharmacokinetics of antidepressants. Expert Opin Drug Metab Toxicol. 2011;7(2):213-226. [pmid: 21192772].
199 Liu H, Umberson D. Gender, stress in childhood and adulthood, and trajectories of change in body mass. Soc Sci Med. 2015;139:61-69. [pmid: 26151391].
200 Power ML, Schulkin J. Sex differences in fat storage, fat metabolism, and the health risks from obesity: possible evolutionary origins. Br J Nutr. 2008;99(5):931-940. [pmid: 17977473].
201 Hughes J, Jouldjian S, Washington DL, Alessi CA, Martin JL. Insomnia and symptoms of post-traumatic stress disorder among women veterans. Behav Sleep Med. 2013;11(4):258-274. [pmid: 23205531].
202 Bielawski MP, Goldstein KM, Mattocks KM, Bean-Mayberry B, Yano EM, Bastian LA. Improving care of chronic conditions for women veterans: identifying opportunities for comparative effectiveness research. J Comp Eff Res. 2014;3(2):155-166. [pmid: 24645689].
203 Ramsberg J, Asseburg C, Henriksson M. Effectiveness and cost-effectiveness of antidepressants in primary care: a multiple treatment comparison meta-analysis and cost-effectiveness model. PLoS One. 2012;7(8):e42003. [pmid: 22876296].
204 Levkovitz Y, Tedeschini E, Papakostas GI. Efficacy of antidepressants for dysthymia: a meta-analysis of placebo-controlled randomized trials. J Clin Psychiatry. 2011;72(4):509-514. [pmid: 21527126].
205 Machado M, Einarson TR. Comparison of SSRIs and SNRIs in major depressive disorder: a meta-analysis of head-to-head randomized clinical trials. (Structured abstract). Journal of Clinical Pharmacy and Therapeutics. 2010;35(2):177-188. http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12010002896/frame.html. [pmid: 20456736].
206 Rocha FL, Fuzikawa C, Riera R, Hara C. Combination of antidepressants in the treatment of major depressive disorder: a systematic review and meta-analysis. J Clin Psychopharmacol. 2012;32(2):278-281. [pmid: 22367652].
207 Schueler YB, Koesters M, Wieseler B, et al. A systematic review of duloxetine and venlafaxine in major depression, including unpublished data. Acta Psychiatr Scand. 2011;123(4):247-265. [pmid: 20831742].
208 Tedeschini E, Levkovitz Y, Iovieno N, Ameral VE, Nelson JC, Papakostas GI. Efficacy of antidepressants for late-life depression: a meta-analysis and meta-regression of placebo-controlled randomized trials. J Clin Psychiatry. 2011;72(12):1660-1668. [pmid: 22244025].
209 Baardseth TP, Goldberg SB, Pace BT, et al. Cognitive-behavioral therapy versus other therapies: redux. Clin Psychol Rev. 2013;33(3):395-405. [pmid: 23416876].
210 Cuijpers P, de Beurs DP, van Spijker BA, Berking M, Andersson G, Kerkhof AJ. The effects of psychotherapy for adult depression on suicidality and hopelessness: a systematic review and meta-analysis. J Affect Disord. 2013;144(3):183-190. [pmid: 22832172].
211 Cuijpers P, Smit F, Bohlmeijer E, Hollon SD, Andersson G. Efficacy of cognitive-behavioural therapy and other psychological treatments for adult depression: meta-analytic study of publication bias. Br J Psychiatry. 2010;196(3):173-178. [pmid: 20194536].
212 Cuijpers P, Koole SL, van Dijke A, Roca M, Li J, Reynolds CF 3rd. Psychotherapy for subclinical depression: meta-analysis. Br J Psychiatry. 2014;205(4):268-274. [pmid: 25274315].
213 Cuijpers P, Turner EH, Mohr DC, et al. Comparison of psychotherapies for adult depression to pill placebo control groups: a meta-analysis. Psychol Med. 2014;44(4):685-695. [pmid: 23552610].
214 Cuijpers P, Geraedts AS, van Oppen P, Andersson G, Markowitz JC, van Straten A. Interpersonal psychotherapy for depression: a meta-analysis. Am J Psychiatry. 2011;168(6):581-592. [pmid: 21362740].
215 Cuijpers P, Sijbrandij M, Koole SL, Andersson G, Beekman AT, Reynolds CF 3rd. The efficacy of psychotherapy and pharmacotherapy in treating depressive and anxiety disorders: a meta-analysis of direct comparisons. World Psychiatry. 2013;12(2):137-148. [pmid: 23737423].
216 Gould RL, Coulson MC, Howard RJ. Cognitive behavioral therapy for depression in older people: a meta-analysis and meta-regression of randomized controlled trials. J Am Geriatr Soc. 2012;60(10):1817-1830. [pmid: 23003115].
217 Hofmann SG, Sawyer AT, Witt AA, Oh D. The effect of mindfulness-based therapy on anxiety and depression: A meta-analytic review. J Consult Clin Psychol. 2010;78(2):169-183. [pmid: 20350028].
218 Jakobsen JC, Lindschou Hansen J, Storebo OJ, Simonsen E, Gluud C. The effects of cognitive therapy versus ‘treatment as usual’ in patients with major depressive disorder. PLoS One. 2011;6(8):e22890. [pmid: 21829664].
219 Jakobsen JC, Hansen JL, Simonsen S, Simonsen E, Gluud C. Effects of cognitive therapy versus interpersonal psychotherapy in patients with major depressive disorder: a systematic review of randomized clinical trials with meta-analyses and trial sequential analyses. Psychol Med. 2012;42(7):1343-1357. [pmid: 22051174].
220 Jakobsen JC, Hansen JL, Simonsen E, Gluud C. The effect of interpersonal psychotherapy and other psychodynamic therapies versus ‘treatment as usual’ in patients with major depressive disorder. PLoS One. 2011;6(4):e19044. [pmid: 21556370].
221 Jakobsen JC, Hansen JL, Storebo OJ, Simonsen E, Gluud C. The effects of cognitive therapy versus ‘no intervention’ for major depressive disorder. PLoS One. 2011;6(12):e28299. [pmid: 22174786].
222 Khoury B, Lecomte T, Fortin G, et al. Mindfulness-based therapy: a comprehensive meta-analysis. Clin Psychol Rev. 2013;33(6):763-771. [pmid: 23796855].
223 Kiosses DN, Leon AC, Arean PA. Psychosocial interventions for late-life major depression: evidence-based treatments, predictors of treatment outcomes, and moderators of treatment effects. Psychiatr Clin North Am. 2011;34(2):377-401. viii. [pmid: 21536164].
224 Krishna M, Jauhari A, Lepping P, Turner J, Crossley D, Krishnamoorthy A. Is group psychotherapy effective in older adults with depression? A systematic review. Int J Geriatr Psychiatry. 2011;26(4):331-340. [pmid: 20973096].
225 Lynch D, Laws KR, McKenna PJ. Cognitive behavioural therapy for major psychiatric disorder: does it really work? A meta-analytical review of well-controlled trials. Psychol Med. 2010;40(1):9-24. [pmid: 19476688].
226 Okumura Y, Ichikura K. Efficacy and acceptability of group cognitive behavioral therapy for depression: a systematic review and meta-analysis. J Affect Disord. 2014;164:155-164. [pmid: 24856569].
227 Samad Z, Brealey S, Gilbody S. The effectiveness of behavioural therapy for the treatment of depression in older adults: a meta-analysis. Int J Geriatr Psychiatry. 2011;26(12):1211-1220. [pmid: 21308789].
228 Spielmans GI, Berman MI, Usitalo AN. Psychotherapy versus second-generation antidepressants in the treatment of depression: a meta-analysis. J Nerv Ment Dis. 2011;199(3):142-149. [pmid: 21346483].
229 van Hees ML, Rotter T, Ellermann T, Evers SM. The effectiveness of individual interpersonal psychotherapy as a treatment for major depressive disorder in adult outpatients: a systematic review. BMC Psychiatry. 2013;13:22. [pmid: 23312024].
230 Andrews G, Cuijpers P, Craske MG, McEvoy P, Titov N. Computer therapy for the anxiety and depressive disorders is effective, acceptable and practical health care: a meta-analysis. PLoS One. 2010;5(10):e13196. [pmid: 20967242].
231 Griffiths KM, Farrer L, Christensen H. The efficacy of internet interventions for depression and anxiety disorders: a review of randomised controlled trials. Med J Aust. 2010;192(11 Suppl):S4-11. [pmid: 20528707].
232 Richards D, Richardson T. Computer-based psychological treatments for depression: a systematic review and meta-analysis. Clin Psychol Rev. 2012;32(4):329-342. [pmid: 22466510].
233 So M, Yamaguchi S, Hashimoto S, Sado M, Furukawa TA, McCrone P. Is computerised CBT really helpful for adult depression?-A meta-analytic re-evaluation of CCBT for adult depression in terms of clinical implementation and methodological validity. BMC Psychiatry. 2013;13:113. [pmid: 23587347].
234 Jakobsen JC, Hansen JL, Simonsen E, Gluud C. The effect of adding psychodynamic therapy to antidepressants in patients with major depressive disorder. A systematic review of randomized clinical trials with meta-analyses and trial sequential analyses. J Affect Disord. 2012;137(1-3):4-14. [pmid: 21501877].
235 Cuijpers P, van Straten A, Hollon SD, Andersson G. The contribution of active medication to combined treatments of psychotherapy and pharmacotherapy for adult depression: a meta-analysis. Acta Psychiatr Scand. 2010;121(6):415-423. [pmid: 19922522].
236 Cuijpers P, Andersson G, Donker T, van Straten A. Psychological treatment of depression: results of a series of meta-analyses. Nord J Psychiatry. 2011;65(6):354-364. [pmid: 21770842].
237 Cuijpers P, Sijbrandij M, Koole SL, Andersson G, Beekman AT, Reynolds CF 3rd. Adding psychotherapy to antidepressant medication in depression and anxiety disorders: a meta-analysis. World Psychiatry. 2014;13(1):56-67. [pmid: 24497254].
238 Cuijpers P, Dekker J, Hollon SD, Andersson G. Adding psychotherapy to pharmacotherapy in the treatment of depressive disorders in adults: a meta-analysis. (Structured abstract). J Clin Psychiatry. 2009;70(9):1219-1229. http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12009109415/frame.html. [pmid: 19818243].
239 Spijker J, van Straten A, Bockting CL, Meeuwissen JA, van Balkom AJ. Psychotherapy, antidepressants, and their combination for chronic major depressive disorder: a systematic review. Can J Psychiatry. 2013;58(7):386-392. [pmid: 23870720].
240 Danielsson L, Noras AM, Waern M, Carlsson J. Exercise in the treatment of major depression: a systematic review grading the quality of evidence. Physiother Theory Pract. 2013;29(8):573-585. [pmid: 23521569].
241 Mura G, Moro MF, Patten SB, Carta MG. Exercise as an add-on strategy for the treatment of major depressive disorder: a systematic review. CNS Spectr. 2014;19(6):496-508. [pmid: 24589012].
242 Cramer H, Lauche R, Langhorst J, Dobos G. Yoga for depression: a systematic review and meta-analysis. Depress Anxiety. 2013;30(11):1068-1083. [pmid: 23922209].
243 Josefsson T, Lindwall M, Archer T. Physical exercise intervention in depressive disorders: meta-analysis and systematic review. Scand J Med Sci Sports. 2014;24(2):259-272. [pmid: 23362828].
244 Silveira H, Moraes H, Oliveira N, Coutinho ES, Laks J, Deslandes A. Physical exercise and clinically depressed patients: a systematic review and meta-analysis. Neuropsychobiology. 2013;67(2):61-68. [pmid: 23295766].
245 Bridle C, Spanjers K, Patel S, Atherton NM, Lamb SE. Effect of exercise on depression severity in older people: systematic review and meta-analysis of randomised controlled trials. Br J Psychiatry. 2012;201(3):180-185. [pmid: 22945926].
246 Krogh J, Nordentoft M, Sterne JA, Lawlor DA. The effect of exercise in clinically depressed adults: systematic review and meta-analysis of randomized controlled trials. J Clin Psychiatry. 2011;72(4):529-538. [pmid: 21034688].
247 Woltmann E, Grogan-Kaylor A, Perron B, Georges H, Kilbourne AM, Bauer MS. Comparative effectiveness of collaborative chronic care models for mental health conditions across primary, specialty, and behavioral health care settings: systematic review and meta-analysis. Am J Psychiatry. 2012;169(8):790-804. [pmid: 22772364].
248 Cuijpers P, van Straten A, Schuurmans J, van Oppen P, Hollon SD, Andersson G. Psychotherapy for chronic major depression and dysthymia: a meta-analysis. Clin Psychol Rev. 2010;30(1):51-62. [pmid: 19781837].
249 Kriston L, von Wolff A, Westphal A, Holzel LP, Harter M. Efficacy and acceptability of acute treatments for persistent depressive disorder: a network meta-analysis. Depress Anxiety. 2014;31(8):621-630. [pmid: 24448972].
250 von Wolff A, Holzel LP, Westphal A, Harter M, Kriston L. Selective serotonin reuptake inhibitors and tricyclic antidepressants in the acute treatment of chronic depression and dysthymia: a systematic review and meta-analysis. J Affect Disord. 2013;144(1-2):7-15. [pmid: 22963896].
251 Krishna M, Honagodu A, Rajendra R, Sundarachar R, Lane S, Lepping P. A systematic review and meta-analysis of group psychotherapy for sub-clinical depression in older adults. Int J Geriatr Psychiatry. 2013;28(9):881-888. [pmid: 23147496].
252 Lee SY, Franchetti MK, Imanbayev A, Gallo JJ, Spira AP, Lee HB. Non-pharmacological prevention of major depression among community-dwelling older adults: a systematic review of the efficacy of psychotherapy interventions. Arch Gerontol Geriatr. 2012;55(3):522-529. [pmid: 22483200].
253 Cameron IM, Reid IC, MacGillivray SA. Efficacy and tolerability of antidepressants for sub-threshold depression and for mild major depressive disorder. J Affect Disord. 2014;166:48-58. [pmid: 25012410].
254 Chiesa A, Serretti A. Mindfulness based cognitive therapy for psychiatric disorders: a systematic review and meta-analysis. Psychiatry Res. 2011;187(3):441-453. [pmid: 20846726].
255 Lopes Rocha F, Fuzikawa C, Riera R, Ramos MG, Hara C. Antidepressant combination for major depression in incomplete responders--a systematic review. J Affect Disord. 2013;144(1-2):1-6. [pmid: 22835845].
256 Feng CY, Chu H, Chen CH, et al. The effect of cognitive behavioral group therapy for depression: a meta-analysis 2000-2010. Worldviews Evid Based Nurs. 2012;9(1):2-17. [pmid: 22221447].
257 Glue P, Donovan MR, Kolluri S, Emir B. Meta-analysis of relapse prevention antidepressant trials in depressive disorders. Aust N Z J Psychiatry. 2010;44(8):697-705. [pmid: 20636190].
258 Guidi J, Fava GA, Fava M, Papakostas GI. Efficacy of the sequential integration of psychotherapy and pharmacotherapy in major depressive disorder: a preliminary meta-analysis. Psychol Med. 2011;41(2):321-331. [pmid: 20444307].
259 Piet J, Hougaard E. The effect of mindfulness-based cognitive therapy for prevention of relapse in recurrent major depressive disorder: a systematic review and meta-analysis. Clin Psychol Rev. 2011;31(6):1032-1040. [pmid: 21802618].
260 Zintzaras E, Miligkos M, Ziakas P, et al. Assessment of the relative effectiveness and tolerability of treatments of type 2 diabetes mellitus: a network meta-analysis. Clin Ther. 2014;36(10):1443-1453.e1449. [pmid: 25109773].
261 Guo X, Liu X, Wang M, Wei F, Zhang Y, Zhang Y. The effects of bariatric procedures versus medical therapy for obese patients with type 2 diabetes: meta-analysis of randomized controlled trials. Biomed Res Int. 2013;2013:410609. [pmid: 23971035].
262 Li JF, Lai DD, Ni B, Sun KX. Comparison of laparoscopic Roux-en-Y gastric bypass with laparoscopic sleeve gastrectomy for morbid obesity or type 2 diabetes mellitus: a meta-analysis of randomized controlled trials. Can J Surg. 2013;56(6):E158-164. [pmid: 24284156].
263 Picot J, Jones J, Colquitt JL, Loveman E, Clegg AJ. Weight loss surgery for mild to moderate obesity: a systematic review and economic evaluation. Obes Surg. 2012;22(9):1496-1506. [pmid: 22926715].
264 Dixon JB, Murphy DK, Segel JE, Finkelstein EA. Impact of laparoscopic adjustable gastric banding on type 2 diabetes. Obes Rev. 2012;13(1):57-67. [pmid: 21880108].
265 Yip S, Plank LD, Murphy R. Gastric bypass and sleeve gastrectomy for type 2 diabetes: a systematic review and meta-analysis of outcomes. Obes Surg. 2013;23(12):1994-2003. [pmid: 23955521].
266 van Vugt M, de Wit M, Cleijne WH, Snoek FJ. Use of behavioral change techniques in web-based self-management programs for type 2 diabetes patients: systematic review. J Med Internet Res. 2013;15(12):e279. [pmid: 24334230].
267 Liang X, Wang Q, Yang X, et al. Effect of mobile phone intervention for diabetes on glycaemic control: a meta-analysis. Diabet Med. 2011;28(4):455-463. [pmid: 21392066].
268 Chudyk A, Petrella RJ. Effects of exercise on cardiovascular risk factors in type 2 diabetes: a meta-analysis. Diabetes Care. 2011;34(5):1228-1237. [pmid: 21525503].
269 Schwingshackl L, Missbach B, Dias S, Konig J, Hoffmann G. Impact of different training modalities on glycaemic control and blood lipids in patients with type 2 diabetes: a systematic review and network meta-analysis. Diabetologia. 2014;57(9):1789-1797. [pmid: 24996616].
270 Vaes AW, Cheung A, Atakhorrami M, et al. Effect of ‘activity monitor-based’ counseling on physical activity and health-related outcomes in patients with chronic diseases: A systematic review and meta-analysis. Ann Med. 2013;45(5-6):397-412. [pmid: 23952917].
271 Hovanec N, Sawant A, Overend TJ, Petrella RJ, Vandervoort AA. Resistance training and older adults with type 2 diabetes mellitus: strength of the evidence. J Aging Res. 2012;2012:284635. [pmid: 22988507].
272 Lee MS, Jun JH, Lim HJ, Lim HS. A systematic review and meta-analysis of tai chi for treating type 2 diabetes. Maturitas. 2015;80(1):14-23. [pmid: 25449822].
273 MacLeod SF, Terada T, Chahal BS, Boule NG. Exercise lowers postprandial glucose but not fasting glucose in type 2 diabetes: a meta-analysis of studies using continuous glucose monitoring. Diabetes Metab Res Rev. 2013;29(8):593-603. [pmid: 24038928].
274 McGinley SK, Armstrong MJ, Boule NG, Sigal RJ. Effects of exercise training using resistance bands on glycaemic control and strength in type 2 diabetes mellitus: a meta-analysis of randomised controlled trials. Acta Diabetol. 2014.
275 Oliveira C, Simoes M, Carvalho J, Ribeiro J. Combined exercise for people with type 2 diabetes mellitus: a systematic review. Diabetes Res Clin Pract. 2012;98(2):187-198. [pmid: 22981711].
276 Umpierre D, Ribeiro PA, Schaan BD, Ribeiro JP. Volume of supervised exercise training impacts glycaemic control in patients with type 2 diabetes: a systematic review with meta-regression analysis. Diabetologia. 2013;56(2):242-251. [pmid: 23160642].
277 Yang Z, Scott CA, Mao C, Tang J, Farmer AJ. Resistance exercise versus aerobic exercise for type 2 diabetes: a systematic review and meta-analysis. Sports Med. 2014;44(4):487-499. [pmid: 24297743].
278 Strasser B, Siebert U, Schobersberger W. Resistance training in the treatment of the metabolic syndrome: a systematic review and meta-analysis of the effect of resistance training on metabolic clustering in patients with abnormal glucose metabolism. Sports Med. 2010;40(5):397-415. [pmid: 20433212].
279 Yan JH, Gu WJ, Pan L. Lack of evidence on Tai Chi-related effects in patients with type 2 diabetes mellitus: a meta-analysis. Exp Clin Endocrinol Diabetes. 2013;121(5):266-271. [pmid: 23450333].
280 Zhou J, Zhang L, Liu H, Mallampati T, Xu M, Yang J. Tai Chi for type 2 diabetes mellitus. Cochrane Database of Systematic Reviews. 2012;(3). http://onlinelibrary.wiley.com/doi/10.1002/14651858.CD009717/abstract.
281 Castaneda-Gonzalez LM, Bacardi Gascon M, Jimenez Cruz A. Effects of low carbohydrate diets on weight and glycemic control among type 2 diabetes individuals: a systemic review of RCT greater than 12 weeks. Nutr Hosp. 2011;26(6):1270-1276. [pmid: 22411372].
282 Dong JY, Zhang ZL, Wang PY, Qin LQ. Effects of high-protein diets on body weight, glycaemic control, blood lipids and blood pressure in type 2 diabetes: meta-analysis of randomised controlled trials. Br J Nutr. 2013;110(5):781-789. [pmid: 23829939].
283 Schwingshackl L, Hoffmann G. Comparison of the long-term effects of high-fat v. low-fat diet consumption on cardiometabolic risk factors in subjects with abnormal glucose metabolism: a systematic review and meta-analysis. Br J Nutr. 2014;111(12):2047-2058. [pmid: 24666665].
284 Ricci-Cabello I, Ruiz-Perez I, Rojas-Garcia A, Pastor G, Goncalves DC. Improving diabetes care in rural areas: a systematic review and meta-analysis of quality improvement interventions in OECD countries. PLoS One. 2013;8(12):e84464. [pmid: 24367662].
285 Searle A, Spink M, Ho A, Chuter V. Exercise interventions for the treatment of chronic low back pain: A systematic review and meta-analysis of randomised controlled trials. Clin Rehabil. 2015.
286 Wang XQ, Zheng JJ, Yu ZW, et al. A meta-analysis of core stability exercise versus general exercise for chronic low back pain. PLoS One. 2012;7(12):e52082. [pmid: 23284879].
287 Schaafsma FG, Whelan K, van der Beek AJ, van der Es-Lambeek LC, Ojajarvi A, Verbeek JH. Physical conditioning as part of a return to work strategy to reduce sickness absence for workers with back pain. Cochrane Database Syst Rev. 2013;8. Cd001822.
288 Ferreira ML, Smeets RJ, Kamper SJ, Ferreira PH, Machado LA. Can we explain heterogeneity among randomized clinical trials of exercise for chronic back pain? A meta-regression analysis of randomized controlled trials. Phys Ther. 2010;90(10):1383-1403. [pmid: 20671101].
289 Fersum KV, Dankaerts W, O'Sullivan PB, et al. Integration of subclassification strategies in randomised controlled clinical trials evaluating manual therapy treatment and exercise therapy for non-specific chronic low back pain: a systematic review. Br J Sports Med. 2010;44(14):1054-1062. [pmid: 19996331].
290 Miyamoto GC, Costa LO, Cabral CM. Efficacy of the Pilates method for pain and disability in patients with chronic nonspecific low back pain: a systematic review with meta-analysis. Braz J Phys Ther. 2013;17(6):517-532. [pmid: 24346291].
291 Pereira LM, Obara K, Dias JM, et al. Comparing the Pilates method with no exercise or lumbar stabilization for pain and functionality in patients with chronic low back pain: systematic review and meta-analysis. Clin Rehabil. 2012;26(1):10-20. [pmid: 21856719].
292 Standaert CJ, Friedly J, Erwin MW, et al. Comparative effectiveness of exercise, acupuncture, and spinal manipulation for low back pain. Spine (Phila Pa 1976). 2011;36(21 Suppl):S120-130. [pmid: 21952184].
293 Orrock PJ, Myers SP. Osteopathic intervention in chronic non-specific low back pain: a systematic review. BMC Musculoskelet Disord. 2013;14:129. [pmid: 23570655].
294 Rubinstein SM, van Middelkoop M, Assendelft WJ, de Boer MR, van Tulder MW. Spinal manipulative therapy for chronic low-back pain. Cochrane Database Syst Rev. 2011;(2). Cd008112.
295 Rubinstein SM, van Middelkoop M, Kuijpers T, et al. A systematic review on the effectiveness of complementary and alternative medicine for chronic non-specific low-back pain. Eur Spine J. 2010;19(8):1213-1228. [pmid: 20229280].
296 Xu M, Yan S, Yin X, et al. Acupuncture for chronic low back pain in long-term follow-up: a meta-analysis of 13 randomized controlled trials. Am J Chin Med. 2013;41(1):1-19. [pmid: 23336503].
297 Falco FJ, Manchikanti L, Datta S, et al. An update of the effectiveness of therapeutic lumbar facet joint interventions. Pain Physician. 2012;15(6):E909-953. [pmid: 23159980].
298 Parr AT, Manchikanti L, Hameed H, et al. Caudal epidural injections in the management of chronic low back pain: a systematic appraisal of the literature. Pain Physician. 2012;15(3):E159-198. [pmid: 22622911].
299 Chou R, Baisden J, Carragee EJ, Resnick DK, Shaffer WO, Loeser JD. Surgery for low back pain: a review of the evidence for an American Pain Society Clinical Practice Guideline. Spine (Phila Pa 1976). 2009;34(10):1094-1109. [pmid: 19363455].
300 van Middelkoop M, Rubinstein SM, Kuijpers T, et al. A systematic review on the effectiveness of physical and rehabilitation interventions for chronic non-specific low back pain. Eur Spine J. 2011;20(1):19-39. [pmid: 20640863].
301 Clarke CL, Ryan CG, Martin DJ. Pain neurophysiology education for the management of individuals with chronic low back pain: systematic review and meta-analysis. Man Ther. 2011;16(6):544-549. [pmid: 21705261].
302 Moore RA, Wiffen PJ, Derry S, Toelle T, Rice AS. Gabapentin for chronic neuropathic pain and fibromyalgia in adults. Cochrane Database Syst Rev. 2014;4. Cd007938.
303 Boyers D, McNamee P, Clarke A, et al. Cost-effectiveness of self-management methods for the treatment of chronic pain in an aging adult population: a systematic review of the literature. Clin J Pain. 2013;29(4):366-375. [pmid: 23042472].
304 Western Ontario and McMaster Universities Osteoarthritis Index (WOMAC). Available at: http://www.rheumatology.org/I-Am-A/Rheumatologist/Research/Clinician-Researchers/Western-Ontario-McMaster-Universities-Osteoarthritis-Index-WOMAC. September 16, 2015.