# METHODS

Our aim was to deliver an evidence map that provides (1) an overview of the volume of studies evaluating interventions for selected high-impact conditions in women Veterans and (2) a set of executive summaries that describe the effects of these interventions and whether there has been evaluation of differential effectiveness in women compared with men (hereafter referred to collectively as “sex effects”).

Consistent with the general principles of evidence mapping, our goal was to provide high-level information about broad questions rather than detailed information on a narrow set of questions. We used a stakeholder-driven approach to identify high-priority conditions and interventions. Given the diversity of interventions and range of prioritized conditions, we focused on systematic reviews in order to best estimate the volume of research and treatment effects. Systematic reviews follow a structured approach to identifying relevant studies and summarize the results, often using quantitative estimates (ie, meta-analyses) to generate pooled effect estimates. For treatment efficacy, we prioritized results from systematic reviews that exclusively used randomized trials for effect estimates. However, we did not conduct a quality assessment of these studies, and estimates of treatment effect should be interpreted cautiously. For adverse effects, we also closely examined systematic reviews that included observational studies. We piloted our methodology in an evidence map of a set of diverse interventions for depressive disorders and presented these results to key stakeholders. We then refined our methods and applied the updated protocols to the remaining conditions of interest.

## TOPIC PRIORITIZATION

We used a forced-rank methodology that included presentation of initial rankings to stakeholders, followed by discussion and reranking to identify conditions for inclusion in the mapping project.23 Stakeholders included representatives from HSR&D Center for the Study of Healthcare Innovation, Health Services Research and Development Service, Office of Research and Development, the Women's Health Research Network, Women's Health Services, and Mental Health Services, Department of Veterans Affairs. We initially selected 34 conditions based on (1) disease prevalence among U.S. women and women Veterans, (2) the burden of disease, (3) the availability and breadth of effective treatments, and (4) women Veterans' priorities for gender-specific care (Appendix A).3,24-28 Given resource capacity, it was agreed with stakeholders that we would address a limited set of these conditions. We used multiple rounds of iterative prioritization to select the final conditions of interest. After the first round, depression and chronic pain were ranked highest, but 4 conditions (obesity, type 2 diabetes, posttraumatic stress disorder, and alcohol use disorder) had very similar prioritization scores. Thus, we submitted these 4 conditions to a second round of priority rating, and diabetes was rated highest priority in this group. We also focused the chronic pain topic to more specific diagnoses in order to better determine eligible interventions and improve interpretation of our results. Our final conditions of interest were the following: (1) depressive disorders, (2) type 2 diabetes, and (3) chronic pain (consisting of 3 diagnoses: chronic low back pain [CLBP], fibromyalgia [FM], and chronic knee pain due to osteoarthritis [knee OA]). For each condition, we selected treatments in broad categories, including medications, behavioral interventions, supervised exercise, and quality improvement interventions. We also included certain condition-specific interventions, such as bariatric surgery for diabetes, and joint injections, acupuncture, and spinal manipulation for chronic back and knee pain (Table 1).

Table 1 Eligible interventions and outcomes for medical conditions of interest

| Depressive disorders | Type 2 diabetes | Chronic pain conditions
Interventions | - Antidepressants; - Psychotherapy; - Guided self-help; - Exercise; - Quality improvement^a^ | - Insulin, oral medications; - Psychoeducation, weight management; - Exercise; - Quality improvement^a^; - Bariatric surgery | - Antidepressants, muscle relaxants, anticonvulsants; - Psychotherapy, biofeedback, mindfulness-based practices; - Guided self-help; - Exercise; - Acupuncture, spinal manipulation; - Joint injections; - Quality improvement^a^
Outcomes | - Symptom severity; - Clinical response and remission; - Functional status, quality of life; - Adverse effects | - Glycemic control; - Weight/body mass index; - Microvascular and macrovascular events; - Mortality; - Adverse effects | - Pain severity; - Fatigue^b^; - Functional status, quality of life; - Mortality; - Adverse effects

a Quality improvement interventions included collaborative care, multidisciplinary care, and technology-enhanced interventions.

b Fatigue was an outcome only for fibromyalgia.

## SEARCH STRATEGY

In collaboration with an expert reference librarian, we searched MEDLINE and the Cochrane Database of Systematic Reviews to identify eligible systematic reviews published from January 1, 2009, through October 31, 2014. Search strategies (Appendix B) used Medical Subject Headings (MeSH) and free-text terms for the conditions of interest, eligible interventions, and systematic reviews. We restricted the search to the past 6 years because systematic reviews are typically outdated within 5 years of publication and because of the likely high volume of relevant reviews.29 In addition to electronic searching, we screened published reviews of reviews for eligible studies.

## STUDY SELECTION

To be included in the evidence map, systematic reviews had to meet the following criteria:

- Design: Systematic reviews must describe a search strategy, eligibility criteria, and an analysis plan. We excluded clinical guidelines, systematic review protocols, and reviews focusing on a single drug unless the drug uniquely represented a class of medications (eg, metformin) or the review used individual patient data (IPD) meta-analysis. We prioritized IPD meta-analysis because these studies are well suited to evaluating moderator effects.30
- Participants: Systematic reviews must focus on adults with one of the eligible conditions (depressive disorders, diabetes, or chronic pain conditions). Reviews that evaluated mixed conditions were included if they reported results separately for an eligible condition.
- Interventions: For each condition, we included interventions in several broad categories, including medications, behavioral interventions (eg, psychotherapy, psychoeducation), exercise performed in organized groups (eg, tai chi, pool therapy) or with behavioral support, self-management strategies, and quality improvement interventions (eg, multidisciplinary care, technology-enhanced interventions). Table 1 summarizes the eligible interventions, including some condition-specific ones. Detailed eligibility criteria are provided in Appendix C.
- Outcomes: For each condition, we focused on outcomes that would be the most relevant for clinical providers and patients, including patient-centered outcomes such as symptoms and health-related quality of life. Refer to Table 1 for a summary and Appendix C for details.
- Timing: Any intervention duration and length of follow-up were eligible.
- Setting: Studies conducted in outpatient settings were preferred, but we accepted those that were in mixed or unclear settings.
- Other criteria: Only English-language systematic reviews published since January 2009 were included. For reviews with multiple publications (eg, technical monograph and journal article) or updated reviews (eg, 2 Cochrane publications by the same group on the same topic), we included only the most recent report, prioritizing the journal article over the monograph.

Two reviewers screened citations for eligibility, and citations deemed potentially relevant by either reviewer were retained for full-text review. Full-text publications were evaluated for eligibility by 2 reviewers; disagreements were resolved through discussion or by a third reviewer.

We anticipated that some interventions for each condition would have few or no systematic reviews that addressed sex effects. To determine the feasibility of a systematic review evaluating sex effects, we selected certain high-interest interventions for further evaluation. For each intervention, we selected the largest recent systematic review and used the list of included primary trials as candidates for review. We then examined those primary trials that randomized at least 75 patients per treatment arm and determined whether they reported sex effects. We chose this sample size criterion in order to limit our evaluation to trials that had the potential to be adequately powered to detect interaction effects (intervention * sex).31 For depressive disorders, we looked at quality improvement interventions or psychotherapy, whereas for diabetes, we focused on diet, physical activity, and culturally tailored psychoeducation. For CLBP, we selected behavioral interventions, and for chronic knee OA, exercise interventions.

## DATA ABSTRACTION

For depressive disorders and chronic pain conditions, we evaluated all eligible systematic reviews. For diabetes, we evaluated all reviews of nonpharmacological interventions and applied an additional procedure to prioritize among the large number of eligible systematic reviews addressing medications (n=120).

To prioritize the diabetes medication articles for abstraction, we first selected all reviews that examined multiple classes of medications and reviews of single-drug classes when there were 6 or fewer reviews per class. For medication classes with more than 6 eligible reviews (ie, metformin, incretin mimetics, insulin, and thiazolidinediones), we selected reviews using the following criteria: evaluated an entire drug class (vs single drug studies), published most recently, published in a top-tier journal (eg, Journal of the American Medical Association, Annals of Internal Medicine, British Medical Journal), conducted by an organization known for high-quality reviews (eg, Cochrane Collaboration), or evaluated outcomes such as glycemic control, cardiovascular events, mortality, or adverse events. The remaining unselected but eligible reviews (n=58) underwent a text search for sex effects and were fully abstracted only if the text search was positive (n=13).

Data were abstracted into a customized DistillerSR database (Evidence Partners Inc., Manotick, ON, Canada) by one reviewer and over-read by a second reviewer. Disagreements were resolved by discussion or by obtaining a third reviewer's opinion when consensus could not be reached. Abstracted data included study design (eg, systematic review with or without meta-analysis, network meta-analysis, or IPD meta-analysis), conditions, interventions, outcomes, the number and design of primary studies, proportion of men and women in included studies, and whether sex effects were part of study aims, analysis plan, and/or results. For studies containing sex-specific results, we also abstracted the number of studies included in the sex analyses, method used for evaluating sex effects (eg, meta-regression, subgroup analyses by study design characteristics), and sex effects of the intervention.

## QUALITY ASSESSMENT

A formal assessment of systematic review methodological rigor was beyond the scope of this project. However, to indicate reviews of higher quality, we recorded whether the review was conducted by the Cochrane Collaboration, the Agency for Healthcare Research and Quality's Evidence-based Practice Centers, or the VA Evidence-based Synthesis Program. These organizations are known for their expertise and high-quality systematic reviews. Further, to help readers interpret estimates of treatment effect, we included review authors' comments on study quality or the overall quality of the evidence, when this was available.

## DATA SYNTHESIS

We used descriptive statistics for the amount and types of evidence for included interventions per condition of interest (Table 2). We generated heat maps and barplots to graphically portray the number of studies (using the review with the largest number of included studies) and number of reviews reporting sex effects for each condition–intervention dyad. We report intervention sex effects in detail, giving priority to reviews using IPD meta-analyses and those originating from organizations known for high-quality reviews.

Table 2 Definitions of statistical approaches used in the included systematic reviews

Term | Definition
Cohen's d | An appropriate measure of effect size for the comparison between 2 means. Cohen's d may be interpreted as the following: small effect=0.2 to <0.5; medium effect=0.5 to <0.8; large effect=0.8 or above.
Effect estimate or effect size (ES) | Refers collectively or generally to different versions of the SMD.
Hazard ratio (HR) | The ratio of the hazards, or chance of events occurring in 2 groups, such as the intervention arm compared with the control arm.
Hedges' g | A variation of Cohen's d that corrects for biases due to small sample sizes.
Individual patient data meta-analysis (IPD) | A specific type of systematic review. Rather than extracting summary (aggregate) data from study publications or from investigators, the original research data are sought directly from the researchers responsible for each study. These data can then be reanalyzed centrally and combined in meta-analyses, if appropriate.
Mean difference (MD) | A summary statistic used in meta-analyses of continuous data when outcomes are measured using the same scale (eg, blood pressure in mmHg). In some cases, an MD will be “weighted” wherein the “weight” given to each study reflects how much influence each study has on the overall results of the meta-analysis, determined by the precision of its estimate of effect.
Odds ratio (OR) | A summary statistic used in meta-analyses for dichotomous outcomes, it is the ratio of the odds of an outcome in 2 groups (eg, the odds of the outcome in intervention patients compared with the odds of the outcome in control patients).
Risk ratio (RR) | A summary statistic used in meta-analyses for dichotomous outcomes. Also called “relative risk,” it is the ratio of the risk of an outcome in 2 groups (eg, the risk of the outcome in intervention patients compared with the risk of the outcome in control patients).
Standardized mean difference (SMD) | A summary statistic used in meta-analyses when the studies all assess the same outcome but measure it in a variety of ways (eg, all studies measure depression but they use different psychometric scales). SMD is the mean difference in outcomes between groups, divided by the standard deviation of the outcome among participants.

The primary goals of this synthesis were to describe the volume of recent systematic reviews, including the number of studies contributing to these reviews, and the number of reviews reporting sex effects. A secondary goal was to give general estimates of treatment effect. For these overall treatment effects, we prioritized higher quality, more recent, and more inclusive systematic reviews. Because there were often multiple reviews addressing the same intervention, we examined reviews for consistency of findings. However, we remind readers that the reviews have not been assessed for quality, and so in some cases the estimates of intervention effect may be incorrect.

## PEER REVIEW

A draft of this report was reviewed by technical experts and clinical leadership. A transcript of their comments and our responses are provided in Appendix D.