# INTRODUCTION

The Veterans Health Administration (VHA) has prioritized systematic, evidence-based improvements in the delivery of healthcare to women Veterans. Women are entering the military at unprecedented rates. Women currently represent more than 20% of recruits, and women Veterans now number more than 2 million, accounting for nearly 8% of the U.S. Veteran population.1,2 The number of women Veterans using VHA services has doubled in the past decade,3 in part as a result of higher enrollment among Veterans returning from Iraq and Afghanistan.2 During the 2012 fiscal year, 362,014 women Veterans sought medical care at VHA facilities, and compared with their male counterparts, they were younger, more ethnically diverse, and more likely to reside in urban areas.3

Women Veterans have distinct health problems and healthcare priorities compared with male Veterans. The burden of mental health disorders, such as depression, is higher for women Veterans compared with male Veterans.4-6 More than one-fifth of women Veterans have been exposed to military sexual trauma,7 and such exposures are associated with higher rates of posttraumatic stress disorder8 and other chronic medical illnesses.9 Musculoskeletal conditions are also highly prevalent, affecting 55.9% of women Veterans.3

While there has been increasing awareness of sex and gender differences in health and healthcare, particularly since national initiatives in the early 1990s to improve participation by women in clinical research,10 there are still significant challenges in applying the clinical evidence base to women. For example, there was only 30% overall participation by women in clinical trials used to support the 2007 American Heart Association guidelines for cardiovascular health in women.11 Additionally, published studies infrequently report or discuss the appropriateness of analyses for sex or gender effects.12,13 This may be due in part to hesitation about discussing subgroup analyses from clinical trials that were underpowered to detect sex differences.14,15 Also, when patients are randomized to treatment groups and subsequently divided according to sex, the latter division is not random.16 The presence of such deficits in our clinical knowledge base is especially concerning given well-documented sex differences in effectiveness and adverse effects for some treatments, including certain medications.17-19 Thus, systematic evaluation of current clinical evidence for sex differences in treatment effectiveness, along with identification of key gaps in our knowledge of these differences, is a critical next step for improving health outcomes for women Veterans.

The VHA's Women's Health Service (WHS) oversees national policy, clinical operations, and research programs that address the healthcare needs of women Veterans. The WHS requested an evidence map to aid prioritization and development of implementation projects and research initiatives. Evidence mapping is an emerging approach that describes key characteristics of existing studies for a broad area of medicine.20-22 In this project, we used evidence mapping to (1) better understand sex differences in intervention outcomes for high-impact medical conditions, (2) identify effective interventions for women, and (3) identify gaps in evidence about the efficacy and effectiveness of interventions in women.