# ABBREVIATIONS TABLE

AHRQ: Agency for Healthcare Research and Quality
CI: Confidence interval
CLBP: Chronic low back pain
ES: Effect size
ESP: Evidence-based Synthesis Program
FM: Fibromyalgia
HSR&D: Health Services Research & Development
IPD: Individual-patient data
MD: Mean difference
MeSH: Medical Subject Heading
OA: Osteoarthritis
QUERI: Quality Enhancement Research Initiative
QI: Quality improvement
RCT: Randomized controlled trial
SMD: Standardized mean difference
SOE: Strength of evidence
VA: Veterans Affairs
VHA: Veterans Health Administration
WMD: Weighted mean difference