# DISCUSSION

We identified 313 recently published systematic reviews evaluating eligible interventions for our 3 prioritized conditions. The most frequently evaluated interventions varied by condition: medications and psychotherapy for depression, medications for diabetes, and multiple interventions (eg, exercise, acupuncture or chiropractic manipulation, antidepressants) for the selected chronic pain conditions. For some eligible interventions in each condition, we were unable to find current reviews. Most reviews limited eligibility to RCTs, and the number of primary studies included ranged from 0 to 347. Systematic reviews varied in their reporting of the proportion of men and women enrolled in primary studies, ranging from a low of 31% of reviews for CLBP to a high of 60% of reviews for depressive disorders. When reported, women were well represented in primary studies for depression, and women predominated in the FM studies; representation in diabetes, CLBP, and knee OA studies was more variable.

Although systematic reviews were numerous, few evaluated sex as a moderator of treatment effects (16% for depressive disorders, 8% for diabetes, and 4% for chronic pain). Additionally, most reviews examining sex effects used meta-regression, a statistical technique that is subject to ecological fallacy and recommended only for moderators that are study design characteristics.103,104 IPD meta-analysis is a more robust approach for evaluating sex effects, but it requires greater resources.30 IPD meta-analysis was used by only a small fraction (n =16) of all included reviews. Table 4 summarizes the gaps in evidence on sex effects.

Table 4 Gaps in evidence on sex effects

Condition | Sex effects not examined | No IPD meta-analysis on sex effects
Depressive disorders | All interventions for relapse prevention, treatment-resistant depression and subsyndromal depression; exercise for any depressive disorder | Psychotherapy, combined antidepressants and psychotherapy, quality improvement
Diabetes | All nonpharmacologic interventions except bariatric surgery | All medications except DPP-4 inhibitors; all nonpharmacologic interventions
Chronic pain | [underlined: CLBP] All interventions except antidepressants and quality improvement [underlined: Knee OA] All interventions | [underlined: CLBP] All interventions [underlined: Knee OA] All interventions

Abbreviations: CLBP=chronic low back pain; DPP-4=dipeptidyl peptidase-4; OA=osteoarthritis

To better understand the feasibility of conducting new reviews comparing treatment effect estimates separately for men and women, we evaluated reports of primary RCTs for 7 different condition–intervention dyads. Overall, we found that a minority of RCTs had sample sizes large enough to examine moderator effects and that only 14% of these (9 of 66) examined interactions between sex and intervention groups. The paucity of RCTs examining sex effects is disappointing but is consistent with previous studies.189,190

To our knowledge, this is the first study to examine the evaluation of sex effects in systematic reviews. Our major finding is that, despite efforts to increase participation of women in trials and a greater focus on possible treatment differences between women and men, the sex distribution of included populations is summarized inconsistently, and evaluations for sex effects are rarely conducted. Thus, we urgently need to address the large gaps in our knowledge of sex differences in treatment effectiveness and adverse effects.

## ACHIEVING ADEQUATE REPRESENTATION OF WOMEN IN CLINICAL STUDIES

In response to underrepresentation of women and minorities, the NIH Revitalization Act of 1993 established guidelines for the inclusion of women in all clinical research studies.191 NIH and other research organizations have called for evaluation of sex effects at all stages of research, from the cellular level to human studies.192 Increased understanding of sex effects can lead to improvements in clinical practice by informing whether sex and gender differences require tailoring of clinical interventions for optimal benefit among women. In a recent example, the U.S. Food and Drug Administration issued sex-specific dosage recommendations for zolpidem in 2013, in response to data about higher adverse effects in women using standard dosing.193 When interventions are found to be differentially effective in men and women, it also provides impetus and rationale for research into more effective treatments for both sexes.

In order for the VA to ensure equitable benefit of VA research, it is important to evaluate sex effects and advance the scientific knowledge of evidence-based approaches to improving care for women Veterans. However, inclusion of women in VA research is particularly challenging because women remain a minority within the Veteran population, and the enrollment of women Veterans in VHA, while growing, remains a relatively low proportion (6.5% in 2012).3 Additionally, multiple barriers exist to the recruitment and retention of women and minorities in clinical trials,194 including fear and distrust of the research enterprise, lack of transportation, interference with work and/or family responsibilities, financial costs, and other burdens as a result of participation. Investing in methods to overcome these barriers will be important for VA.

Recognizing the needs and challenges associated with enrolling women, the VA established the Women's Health Research Network to facilitate research participation by women Veterans and encourage investigation of topics important for women Veterans' health.195,196 This network is working to increase research capacity in VA by (1) informing VA investigators about issues important for women Veterans' health and health care, (2) providing training in oversampling techniques and subgroup analyses, and (3) developing a national practice-based research network to facilitate enrollment.195,196

## PRIORITIZING AREAS FOR EVALUATION OF SEX EFFECTS

While evaluating sex effects is important, it can be costly. Examining moderator effects requires larger sample sizes, and the current lack of reporting on sex effects by clinical studies may be due in part to hesitance around identification of spurious subgroup effects in underpowered studies.15 IPD meta-analysis could overcome small sample sizes in primary studies, but this requires cooperation and willingness to share data among investigators, more resources for data repositories, and adequate protections for patient privacy.197 Therefore, the research community needs guiding principles for when information on sex effects is likely to be worth the additional resources needed. We suggest several sources for consideration that could prompt designing new clinical studies to evaluate sex or gender effects:

- Basic science and early-phase clinical studies that suggest differential sex effects (eg, animal models, genomic evidence, pharmacokinetics);
- Observational studies or small RCTs that indicate differential effects; however, limitations in study design or statistical power decrease confidence in such findings;
- Effects of unique biological events, such as menopause, that may alter the risk of disease or response to therapies;
- Conceptual or theoretical models where knowledge of behavioral effects and other social science constructs strongly suggest a sex effect.

The following examples illustrate the application of these criteria. First, antidepressants are used for a wide range of conditions including depressive disorders and chronic pain syndromes. Pharmacokinetic evidence198 supports different antidepressant doses for men and women. In the systematic reviews we evaluated, limited data suggested that adverse effects may differ for men and women with some antidepressants. Since adverse effects are a major cause of poor medication adherence, a better understanding of sex effects in adverse effects for different antidepressants could help clinicians tailor treatment.

Second, for diabetes interventions, multiple medications (eg, insulin and sulfonylureas) were associated with weight gain, but there was no evaluation of sex effects for this adverse outcome. There are many reasons why the effects of weight gain may be different between men and women, including physiologic, behavioral, and social factors.199,200 Further, women may prioritize this outcome more than men, making knowledge of sex effects for weight gain particularly relevant for women.

Third, in examining the treatment of chronic pain, we found one review showing that multicomponent interventions for CLBP may be more effective in women. There are multiple reasons why these multifaceted interventions may have different efficacy in women when compared with men. One possibility is that such interventions lead to better incorporation and coordination of behavioral components, which may be more acceptable to women and even preferable over medications. For example, similar preferences for behavioral interventions have been found in the context of insomnia treatment for women Veterans.201 Additionally, multicomponent interventions could more robustly manage comorbidities, such as sleep disorders and mental health diagnoses, which are more common among women and highly prevalent among women Veterans.3,202 Thus, it would be valuable to confirm the presence of sex effects using IPD meta-analyses, as well as further evaluate the possibly differential role of key intervention components.

Additionally, it would be worthwhile to systematically evaluate how sex differences in preference for treatment type, including complementary and alternative treatments, would affect acceptability, adherence, and efficacy. Some work has shown that women Veterans may be more likely to prefer these treatments for pain,202 but we are lacking information on how these preferences impact actual use and efficacy.

## STUDY LIMITATIONS

Evidence maps are designed to give a broad overview of the evidence base. Our results are best used to describe areas where research has been conducted and where sex effects have been evaluated. However, we evaluated only systematic reviews published since 2009, so we may have missed older reviews of interventions. Also, we did not formally evaluate the quality of included reviews, and so our estimates of intervention effects should be considered preliminary. Reviews that found no evidence of differential intervention effects for men and women may have simply been underpowered to detect a clinically important difference. For IPD meta-analyses, we used an inclusive definition and allowed reviews that simply used available datasets, often from industry-sponsored trials, instead of requiring that such analyses systematically identify all eligible trials. When studies included in IPD meta-analyses are selected for convenience rather than systematically, selection bias can compromise the findings.

## CONCLUSION

There is a large body of evidence for many of the examined interventions, particularly medications, psychotherapy, and exercise. However, systematic reviews and RCTs examined sex effects infrequently. When examined, sex effects generally favored greater benefits in women, but the differential effects were small and the analysis approaches were suboptimal. All RCTs and systematic reviews should report the proportion of men and women enrolled, and sex effects should be examined in adequately powered RCTs or IPD meta-analyses.