# SYSTEMATIC REVIEW REFERENCES BY CONDITION

This appendix lists full citations for included systematic reviews in alphabetical order by condition. The asterisk beside a reference indicates the review reported sex effects.

## Depressive Disorders (86)

Andrews G, Cuijpers P, Craske MG, et al. Computer therapy for the anxiety and depressive disorders is effective, acceptable and practical health care: a meta-analysis. PLoS One. 2010;5(10):e13196. [pmid: 20967242].
Baardseth TP, Goldberg SB, Pace BT, et al. Cognitive-behavioral therapy versus other therapies: redux. Clin Psychol Rev. 2013;33(3):395-405. [pmid: 23416876].
*Bower P Kontopantelis E Sutton A Influence of initial severity of depression on effectiveness of low intensity interventions: meta-analysis of individual patient data BMJ 2013 346 f540 23444423
*Braun SR Gregor B Tran US Comparing bona fide psychotherapies of depression in adults with two meta-analytical approaches PLoS One 2013 8 6 e68135 23840824
Bridle C, Spanjers K, Patel S, Atherton NM, Lamb SE. Effect of exercise on depression severity in older people: systematic review and meta-analysis of randomised controlled trials. Br J Psychiatry. 2012;201(3):180-185. [pmid: 22945926].
*Calati R Salvina Signorelli M Balestri M Antidepressants in elderly: metaregression of double-blind, randomized clinical trials J Affect Disord 2013 147 1-3 1 8 23245467
Cameron IM, Reid IC, MacGillivray SA. Efficacy and tolerability of antidepressants for sub-threshold depression and for mild major depressive disorder. J Affect Disord. 2014;166:48-58. [pmid: 25012410].
Carpenter DJ, Fong R, Kraus JE, et al. Meta-analysis of efficacy and treatment-emergent suicidality in adults by psychiatric indication and age subgroup following initiation of paroxetine therapy: a complete set of randomized placebo-controlled trials. J Clin Psychiatry. 2011;72(11):1503-14. [pmid: 21367354].
*Carter GC Cantrell RA Victoria Z Comprehensive review of factors implicated in the heterogeneity of response in depression Depress Anxiety 2012 29 4 340 54 22511365
Chiesa A, Serretti A. Mindfulness based cognitive therapy for psychiatric disorders: a systematic review and meta-analysis. Psychiatry Res. 2011;187(3):441-53. [pmid: 20846726].
Churchill R, Moore TH, Furukawa TA, et al. “Third wave” cognitive and behavioural therapies versus treatment as usual for depression. Cochrane Database Syst Rev. 2013;10. Cd008705. [pmid: 24142810].
Cramer H, Lauche R, Langhorst J, Dobos G. Yoga for depression: a systematic review and meta-analysis. Depress Anxiety. 2013;30(11):1068-1083. [pmid: 23922209].
Cuijpers P, Andersson G, Donker T, et al. Psychological treatment of depression: results of a series of meta-analyses. Nord J Psychiatry. 2011;65(6):354-64. [pmid: 21770842].
Cuijpers P, de Beurs DP, van Spijker BA, et al. The effects of psychotherapy for adult depression on suicidality and hopelessness: a systematic review and meta-analysis. J Affect Disord. 2013;144(3):183-90. [pmid: 22832172].
Cuijpers P, Dekker J, Hollon SD, et al. Adding psychotherapy to pharmacotherapy in the treatment of depressive disorders in adults: a meta-analysis. (Structured abstract). J Clin Psychiatry. 2009;70:1219-1229. [pmid: 19818243].
Cuijpers P, Geraedts AS, van Oppen P, et al. Interpersonal psychotherapy for depression: a meta-analysis. Am J Psychiatry. 2011;168(6):581-92. [pmid: 21362740].
Cuijpers P, Karyotaki E, Weitz E, et al. The effects of psychotherapies for major depression in adults on remission, recovery and improvement: a meta-analysis. J Affect Disord. 2014;159:118-26. [pmid: 24679399].
Cuijpers P, Koole SL, van Dijke A, et al. Psychotherapy for subclinical depression: meta-analysis. Br J Psychiatry. 2014;205(4):268-274. [pmid: 25274315].
*Cuijpers P Reynolds CF 3rd Donker T Personalized treatment of adult depression: medication, psychotherapy, or both? A systematic review Depress Anxiety 2012 29 10 855 64 22815247
Cuijpers P, Sijbrandij M, Koole SL, et al. The efficacy of psychotherapy and pharmacotherapy in treating depressive and anxiety disorders: a meta-analysis of direct comparisons. World Psychiatry. 2013;12(2):137-48. [pmid: 23737423].
Cuijpers P, Sijbrandij M, Koole SL, et al. Adding psychotherapy to antidepressant medication in depression and anxiety disorders: a meta-analysis. World Psychiatry. 2014;13(1):56-67. [pmid: 24497254].
Cuijpers P, Smit F, Bohlmeijer E, et al. Efficacy of cognitive-behavioural therapy and other psychological treatments for adult depression: meta-analytic study of publication bias. Br J Psychiatry. 2010;196(3):173-8. [pmid: 20194536].
Cuijpers P, Turner EH, Mohr DC, et al. Comparison of psychotherapies for adult depression to pill placebo control groups: a meta-analysis. Psychol Med. 2014;44(4):685-95. [pmid: 23552610].
Cuijpers P, van Straten A, Bohlmeijer E, et al. The effects of psychotherapy for adult depression are overestimated: a meta-analysis of study quality and effect size. Psychol Med. 2010;40(2):211-23. [pmid: 19490745].
Cuijpers P, van Straten A, Hollon SD, et al. The contribution of active medication to combined treatments of psychotherapy and pharmacotherapy for adult depression: a meta-analysis. Acta Psychiatr Scand. 2010;121(6):415-23. [pmid: 19922522].
Cuijpers P, van Straten A, Schuurmans J, et al. Psychotherapy for chronic major depression and dysthymia: a meta-analysis. Clin Psychol Rev. 2010;30(1):51-62. [pmid: 19781837].
Danielsson L, Noras AM, Waern M, et al. Exercise in the treatment of major depression: a systematic review grading the quality of evidence. Physiother Theory Pract. 2013;29(8):573-85. [pmid: 23521569].
*Driessen E Cuijpers P de Maat SC The efficacy of short-term psychodynamic psychotherapy for depression: a meta-analysis Clin Psychol Rev 2010 30 1 25 36 19766369
Driessen E, Cuijpers P, Hollon SD, et al. Does pretreatment severity moderate the efficacy of psychological treatment of adult outpatient depression? A meta-analysis. J Consult Clin Psychol. 2010;78(5):668-80. [pmid: 20873902].
Feng CY, Chu H, Chen CH, et al. The effect of cognitive behavioral group therapy for depression: a meta-analysis 2000-2010. Worldviews Evid Based Nurs. 2012;9(1):2-17. [pmid: 22221447].
Fournier JC, DeRubeis RJ, Hollon SD, et al. Antidepressant drug effects and depression severity: a patient-level meta-analysis. JAMA. 2010;303(1):47-53. [pmid: 20051569].
*Gartlehner G Hansen RA Morgan LC Comparative benefits and harms of second-generation antidepressants for treating major depressive disorder: an updated meta-analysis Ann Intern Med 2011 155 11 772 85 22147715
Gibbons RD, Brown CH, Hur K, et al. Suicidal thoughts and behavior with antidepressant treatment: reanalysis of the randomized placebo-controlled studies of fluoxetine and venlafaxine. Arch Gen Psychiatry. 2012;69(6):580-7. [pmid: 22309973].
Gibbons RD, Hur K, Brown CH, et al. Benefits from antidepressants: synthesis of 6-week patient-level outcomes from double-blind placebo-controlled randomized trials of fluoxetine and venlafaxine. Arch Gen Psychiatry. 2012;69(6):572-9. [pmid: 22393205].
*Gibiino S Marsano A Serretti A Specificity profile of venlafaxine and sertraline in major depression: metaregression of double-blind, randomized clinical trials (Provisional abstract) International Journal of Neuropsychopharmacology 17 2014 1 8 23953038
Glue P, Donovan MR, Kolluri S, et al. Meta-analysis of relapse prevention antidepressant trials in depressive disorders. Aust N Z J Psychiatry. 2010;44(8):697-705. [pmid: 20636190].
Gould RL, Coulson MC, Howard RJ. Cognitive behavioral therapy for depression in older people: a meta-analysis and meta-regression of randomized controlled trials. J Am Geriatr Soc. 2012;60(10):1817-30. [pmid: 23003115].
Griffiths KM, Farrer L, Christensen H. The efficacy of internet interventions for depression and anxiety disorders: a review of randomised controlled trials. Med J Aust. 2010;192(11 Suppl):S4-11. [pmid: 20528707].
Guidi J, Fava GA, Fava M, et al. Efficacy of the sequential integration of psychotherapy and pharmacotherapy in major depressive disorder: a preliminary meta-analysis. Psychol Med. 2011;41(2):321-31. [pmid: 20444307].
Hofmann SG, Sawyer AT, Witt AA, et al. The effect of mindfulness-based therapy on anxiety and depression: A meta-analytic review. J Consult Clin Psychol. 2010;78(2):169-83. [pmid: 20350028].
Hunot V, Moore TH, Caldwell DM, et al. “Third wave” cognitive and behavioural therapies versus other psychological therapies for depression. Cochrane Database Syst Rev. 2013;10. Cd008704. [pmid: 24142844].
Jakobsen JC, Hansen JL, Simonsen E, et al. The effect of interpersonal psychotherapy and other psychodynamic therapies versus ‘treatment as usual’ in patients with major depressive disorder. PLoS One. 2011;6(4):e19044. [pmid: 21556370].
Jakobsen JC, Hansen JL, Simonsen E, et al. The effect of adding psychodynamic therapy to antidepressants in patients with major depressive disorder. A systematic review of randomized clinical trials with meta-analyses and trial sequential analyses. J Affect Disord. 2012;137(1-3):4-14. [pmid: 21501877].
Jakobsen JC, Hansen JL, Simonsen S, et al. Effects of cognitive therapy versus interpersonal psychotherapy in patients with major depressive disorder: a systematic review of randomized clinical trials with meta-analyses and trial sequential analyses. Psychol Med. 2012;42(7):1343-57. [pmid: 22051174].
Jakobsen JC, Hansen JL, Storebo OJ, et al. The effects of cognitive therapy versus ‘no intervention’ for major depressive disorder. PLoS One. 2011;6(12):e28299. [pmid: 22174786].
Jakobsen JC, Lindschou Hansen J, Storebo OJ, et al. The effects of cognitive therapy versus ‘treatment as usual’ in patients with major depressive disorder. PLoS One. 2011;6(8):e22890. [pmid: 21829664].
Josefsson T, Lindwall M, Archer T. Physical exercise intervention in depressive disorders: meta-analysis and systematic review. Scand J Med Sci Sports. 2014;24(2):259-272. [pmid: 23362828].
Kasper S, Corruble E, Hale A, et al. Antidepressant efficacy of agomelatine versus SSRI/SNRI: results from a pooled analysis of head-to-head studies without a placebo control. Int Clin Psychopharmacol. 2013;28(1):12-9. [pmid: 23023074].
Kennedy SH, Andersen HF, Thase ME. Escitalopram in the treatment of major depressive disorder: a meta-analysis. (Structured abstract). Current Medical Research and Opinion. 2009;25:161-175. [pmid: 19210149].
Khoury B, Lecomte T, Fortin G, et al. Mindfulness-based therapy: a comprehensive meta-analysis. Clin Psychol Rev. 2013;33(6):763-71. [pmid: 23796855].
Kiosses DN, Leon AC, Arean PA. Psychosocial interventions for late-life major depression: evidence-based treatments, predictors of treatment outcomes, and moderators of treatment effects. Psychiatr Clin North Am. 2011;34(2):377-401. viii. [pmid: 21536164].
Krishna M, Honagodu A, Rajendra R, et al. A systematic review and meta-analysis of group psychotherapy for sub-clinical depression in older adults. Int J Geriatr Psychiatry. 2013;28(9):881-8. [pmid: 23147496].
Krishna M, Jauhari A, Lepping P, et al. Is group psychotherapy effective in older adults with depression? A systematic review. Int J Geriatr Psychiatry. 2011;26(4):331-40. [pmid: 20973096].
Kriston L, von Wolff A, Westphal A, et al. Efficacy and acceptability of acute treatments for persistent depressive disorder: a network meta-analysis. Depress Anxiety. 2014;31(8):621-30. [pmid: 24448972].
Krogh J, Nordentoft M, Sterne JA, Lawlor DA. The effect of exercise in clinically depressed adults: systematic review and meta-analysis of randomized controlled trials. J Clin Psychiatry. 2011;72(4):529-538. [pmid: 21034688].
Lee SY, Franchetti MK, Imanbayev A, et al. Non-pharmacological prevention of major depression among community-dwelling older adults: a systematic review of the efficacy of psychotherapy interventions. Arch Gerontol Geriatr. 2012;55(3):522-9. [pmid: 22483200].
Levkovitz Y, Tedeschini E, Papakostas GI. Efficacy of antidepressants for dysthymia: a meta-analysis of placebo-controlled randomized trials. J Clin Psychiatry. 2011;72(4):509-14. [pmid: 21527126].
Lopes Rocha F, Fuzikawa C, Riera R, et al. Antidepressant combination for major depression in incomplete responders--a systematic review. J Affect Disord. 2013;144(1-2):1-6. [pmid: 22835845].
Lynch D, Laws KR, McKenna PJ. Cognitive behavioural therapy for major psychiatric disorder: does it really work? A meta-analytical review of well-controlled trials. Psychol Med. 2010;40(1):9-24. [pmid: 19476688].
Machado M, Einarson TR. Comparison of SSRIs and SNRIs in major depressive disorder: a meta-analysis of head-to-head randomized clinical trials. (Structured abstract). Journal of Clinical Pharmacy and Therapeutics. 2010;35:177-188. [pmid: 20456736].
*Mancini M Sheehan DV Demyttenaere K Evaluation of the effect of duloxetine treatment on functioning as measured by the Sheehan disability scale: pooled analysis of data from six randomized, double-blind, placebo-controlled clinical studies Int Clin Psychopharmacol 2012 27 6 298 309 22954893
Mura G, Moro MF, Patten SB, Carta MG. Exercise as an add-on strategy for the treatment of major depressive disorder: a systematic review. CNS Spectr. 2014;19(6):496-508. [pmid: 24589012].
Nieuwsma JA, Trivedi RB, McDuffie J, et al. Brief psychotherapy for depression: a systematic review and meta-analysis. Int J Psychiatry Med. 2012;43(2):129-51. [pmid: 22849036].
Okumura Y, Ichikura K. Efficacy and acceptability of group cognitive behavioral therapy for depression: a systematic review and meta-analysis. J Affect Disord. 2014;164:155-64. [pmid: 24856569].
Papakostas GI, Culpepper L, Fayyad RS, et al. Efficacy of desvenlafaxine 50 mg compared with placebo in patients with moderate or severe major depressive disorder: a pooled analysis of six randomized, double-blind, placebo-controlled studies. (Provisional abstract). Database of Abstracts of Reviews of Effects. 2013:312-321.
Piet J, Hougaard E. The effect of mindfulness-based cognitive therapy for prevention of relapse in recurrent major depressive disorder: a systematic review and meta-analysis. Clin Psychol Rev. 2011;31(6):1032-40. [pmid: 21802618].
Ramsberg J, Asseburg C, Henriksson M. Effectiveness and cost-effectiveness of antidepressants in primary care: a multiple treatment comparison meta-analysis and cost-effectiveness model. PLoS One. 2012;7(8):e42003. [pmid: 22876296].
Richards D, Richardson T. Computer-based psychological treatments for depression: a systematic review and meta-analysis. Clin Psychol Rev. 2012;32(4):329-42. [pmid: 22466510].
Rocha FL, Fuzikawa C, Riera R, et al. Combination of antidepressants in the treatment of major depressive disorder: a systematic review and meta-analysis. J Clin Psychopharmacol. 2012;32(2):278-81. [pmid: 22367652].
*Roshanaei-Moghaddam B Pauly MC Atkins DC Relative effects of CBT and pharmacotherapy in depression versus anxiety: is medication somewhat better for depression, and CBT somewhat better for anxiety? Depress Anxiety 2011 28 7 560 7 21608087
Rubenstein LV, Williams JW Jr., Danz M, Shekelle P, Suttorp M, Johnsen B. VA Evidence-based Synthesis Program Reports. Determining Key Features of Effective Depression Interventions. Washington (DC). Department of Veterans Affairs (US). 2009.
Samad Z, Brealey S, Gilbody S. The effectiveness of behavioural therapy for the treatment of depression in older adults: a meta-analysis. Int J Geriatr Psychiatry. 2011;26(12):1211-20. [pmid: 21308789].
Schueler YB, Koesters M, Wieseler B, et al. A systematic review of duloxetine and venlafaxine in major depression, including unpublished data. Acta Psychiatr Scand. 2011;123(4):247-65. [pmid: 20831742].
Shinohara K, Honyashiki M, Imai H, et al. Behavioural therapies versus other psychological therapies for depression. Cochrane Database Syst Rev. 2013;10. Cd008696. [pmid: 24129886].
Silveira H, Moraes H, Oliveira N, Coutinho ES, Laks J, Deslandes A. Physical exercise and clinically depressed patients: a systematic review and meta-analysis. Neuropsychobiology. 2013;67(2):61-68. [pmid: 23295766].
So M, Yamaguchi S, Hashimoto S, et al. Is computerised CBT really helpful for adult depression?-A meta-analytic re-evaluation of CCBT for adult depression in terms of clinical implementation and methodological validity. BMC Psychiatry. 2013;13:113. [pmid: 23587347].
*Soares CN Fayyad RS Guico-Pabia CJ Early improvement in depressive symptoms with desvenlafaxine 50 mg/d as a predictor of treatment success in patients with major depressive disorder J Clin Psychopharmacol 2014 34 1 57 65 24346751
Spielmans GI, Berman MI, Usitalo AN. Psychotherapy versus second-generation antidepressants in the treatment of depression: a meta-analysis. J Nerv Ment Dis. 2011;199(3):142-9. [pmid: 21346483].
Spijker J, van Straten A, Bockting CL, et al. Psychotherapy, antidepressants, and their combination for chronic major depressive disorder: a systematic review. Can J Psychiatry. 2013;58(7):386-92. [pmid: 23870720].
Tedeschini E, Levkovitz Y, Iovieno N, et al. Efficacy of antidepressants for late-life depression: a meta-analysis and meta-regression of placebo-controlled randomized trials. J Clin Psychiatry. 2011;72(12):1660-8. [pmid: 22244025].
*Thota AB Sipe TA Byard GJ Collaborative care to improve the management of depressive disorders: a community guide systematic review and meta-analysis Am J Prev Med 2012 42 5 525 38 22516495
Trivedi RB, Nieuwsma JA, Williams JW Jr. Examination of the utility of psychotherapy for patients with treatment resistant depression: a systematic review. J Gen Intern Med. 2011;26(6):643-50. [pmid: 21184287].
van Hees ML, Rotter T, Ellermann T, et al. The effectiveness of individual interpersonal psychotherapy as a treatment for major depressive disorder in adult outpatients: a systematic review. BMC Psychiatry. 2013;13:22. [pmid: 23312024].
*von Wolff A Holzel LP Westphal A Combination of pharmacotherapy and psychotherapy in the treatment of chronic depression: a systematic review and meta-analysis BMC Psychiatry 2012 12 61 22694751
von Wolff A, Holzel LP, Westphal A, et al. Selective serotonin reuptake inhibitors and tricyclic antidepressants in the acute treatment of chronic depression and dysthymia: a systematic review and meta-analysis. J Affect Disord. 2013;144(1-2):7-15. [pmid: 22963896].
Woltmann E, Grogan-Kaylor A, Perron B, et al. Comparative effectiveness of collaborative chronic care models for mental health conditions across primary, specialty, and behavioral health care settings: systematic review and meta-analysis. Am J Psychiatry. 2012;169(8):790-804. [pmid: 22772364].

## Type 2 Diabetes (114)

Abdul-Ghani MA, Williams K, Kanat M, et al. Insulin vs GLP-1 analogues in poorly controlled Type 2 diabetic subjects on oral therapy: a meta-analysis. J Endocrinol Invest. 2013;36(3):168-73. [pmid: 22522662].
Ajala O, English P, Pinkney J. Systematic review and meta-analysis of different dietary approaches to the management of type 2 diabetes. Am J Clin Nutr. 2013;97(3):505-16. [pmid: 23364002].
Aroda VR, Henry RR, Han J, et al. Efficacy of GLP-1 receptor agonists and DPP-4 inhibitors: meta-analysis and systematic review. Clin Ther. 2012;34(6):1247-1258.e22. [pmid: 22608780].
Attridge M, Creamer J, Ramsden M, et al. Culturally appropriate health education for people in ethnic minority groups with type 2 diabetes mellitus. Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2014.
Avery L, Flynn D, van Wersch A, et al. Changing physical activity behavior in type 2 diabetes: a systematic review and meta-analysis of behavioral interventions. Diabetes Care. 2012;35(12):2681-9. [pmid: 23173137].
Bennett WL, Maruthur NM, Singh S, et al. Comparative effectiveness and safety of medications for type 2 diabetes: an update including new drugs and 2-drug combinations. Ann Intern Med. 2011;154(9):602-13. [pmid: 21403054].
Bosetti C, Rosato V, Buniato D, Zambon A, La Vecchia C, Corrao G. Cancer risk for patients using thiazolidinediones for type 2 diabetes: a meta-analysis. Oncologist. 2013;18(2):148-156. [pmid: 23345544].
Boussageon R, Supper I, Bejan-Angoulvant T, et al. Reappraisal of metformin efficacy in the treatment of type 2 diabetes: a meta-analysis of randomised controlled trials. PLoS Med. 2012;9(4):e1001204. [pmid: 22509138].
Castaneda-Gonzalez LM, Bacardi Gascon M, Jimenez Cruz A. Effects of low carbohydrate diets on weight and glycemic control among type 2 diabetes individuals: a systemic review of RCT greater than 12 weeks. Nutr Hosp. 2011;26(6):1270-6. [pmid: 22411372].
Chapell R, Gould AL, Alexander CM. Baseline differences in A1C explain apparent differences in efficacy of sitagliptin, rosiglitazone and pioglitazone. Diabetes Obes Metab. 2009;11(11):1009-16. [pmid: 19614948].
Chudyk A, Petrella RJ. Effects of exercise on cardiovascular risk factors in type 2 diabetes: a meta-analysis. Diabetes Care. 2011;34(5):1228-37. [pmid: 21525503].
Cleveringa FG, Gorter KJ, van den Donk M, et al. Computerized decision support systems in primary care for type 2 diabetes patients only improve patients' outcomes when combined with feedback on performance and case management: a systematic review. Diabetes Technol Ther. 2013;15(2):180-92. [pmid: 23360424].
Col NF, Ochs L, Springmann V, et al. Metformin and breast cancer risk: a meta-analysis and critical literature review. Breast Cancer Res Treat. 2012;135(3):639-46. [pmid: 22847511].
Colmers IN, Bowker SL, Majumdar SR, Johnson JA. Use of thiazolidinediones and the risk of bladder cancer among people with type 2 diabetes: a meta-analysis. Cmaj. 2012;184(12):E675-683. [pmid: 22761478].
Colmers IN, Bowker SL, Tjosvold LA, et al. Insulin use and cancer risk in patients with type 2 diabetes: a systematic review and meta-analysis of observational studies. Diabetes Metab. 2012;38(6):485-506. [pmid: 23159131].
Cramer H, Lauche R, Haller H, et al. Effects of yoga on cardiovascular disease risk factors: a systematic review and meta-analysis. Int J Cardiol. 2014;173(2):170-83. [pmid: 24636547].
Decensi A, Puntoni M, Goodwin P, et al. Metformin and cancer risk in diabetic patients: a systematic review and meta-analysis. Cancer Prev Res (Phila). 2010;3(11):1451-1461. [pmid: 20947488].
Dixon JB, Murphy DK, Segel JE, et al. Impact of laparoscopic adjustable gastric banding on type 2 diabetes. Obes Rev. 2012;13(1):57-67. [pmid: 21880108].
Dong JY, Zhang ZL, Wang PY, et al. Effects of high-protein diets on body weight, glycaemic control, blood lipids and blood pressure in type 2 diabetes: meta-analysis of randomised controlled trials. Br J Nutr. 2013;110(5):781-9. [pmid: 23829939].
Egginton JS, Ridgeway JL, Shah ND, et al. Care management for Type 2 diabetes in the United States: a systematic review and meta-analysis. BMC Health Serv Res. 2012;12:72. [pmid: 22439920].
*Esposito K Chiodini P Bellastella G Proportion of patients at HbA1c target <7% with eight classes of antidiabetic drugs in type 2 diabetes: systematic review of 218 randomized controlled trials with 78 945 patients Diabetes Obes Metab 2012 14 3 228 33 21958121
*Esposito K Cozzolino D Bellastella G Dipeptidyl peptidase-4 inhibitors and HbA1c target of <7% in type 2 diabetes: meta-analysis of randomized controlled trials Diabetes Obes Metab 2011 13 7 594 603 21320267
*Fakhoury WK Lereun C Wright D A meta-analysis of placebo-controlled clinical trials assessing the efficacy and safety of incretin-based medications in patients with type 2 diabetes Pharmacology 2010 86 1 44 57 20616619
Fonseca V, Gill J, Zhou R, et al. An analysis of early insulin glargine added to metformin with or without sulfonylurea: impact on glycaemic control and hypoglycaemia. Diabetes Obes Metab. 2011;13(9):814-22. [pmid: 21481127].
Forst T, Hanefeld M, Jacob S, et al. Association of sulphonylurea treatment with all-cause and cardiovascular mortality: a systematic review and meta-analysis of observational studies. Diab Vasc Dis Res. 2013;10(4):302-14. [pmid: 23291340].
Franciosi M, Lucisano G, Lapice E, et al. Metformin therapy and risk of cancer in patients with type 2 diabetes: systematic review. PLoS One. 2013;8(8):e71583. [pmid: 23936520].
Fried M, Ribaric G, Buchwald JN, et al. Metabolic surgery for the treatment of type 2 diabetes in patients with BMI <35 kg/m2: an integrative review of early studies. Obes Surg. 2010;20(6):776-90. [pmid: 20333558].
Gill RS, Birch DW, Shi X, et al. Sleeve gastrectomy and type 2 diabetes mellitus: a systematic review. Surg Obes Relat Dis. 2010;6(6):707-13. [pmid: 20947447].
Goossen K, Graber S. Longer term safety of dipeptidyl peptidase-4 inhibitors in patients with type 2 diabetes mellitus: systematic review and meta-analysis. Diabetes Obes Metab. 2012;14(12):1061-72. [pmid: 22519906].
*Groop PH Del Prato S Taskinen MR Linagliptin treatment in subjects with type 2 diabetes with and without mild-to-moderate renal impairment Diabetes Obes Metab 2014 16 6 560 8 24612167
Gross JL, Kramer CK, Leitao CB, et al. Effect of antihyperglycemic agents added to metformin and a sulfonylurea on glycemic control and weight gain in type 2 diabetes: a network meta-analysis. Ann Intern Med. 2011;154(10):672-9. [pmid: 21576535].
*Gucciardi E Chan VW Manuel L A systematic literature review of diabetes self-management education features to improve diabetes education in women of Black African/Caribbean and Hispanic/Latin American ethnicity Patient Educ Couns 2013 92 2 235 45 23566428
Guo X, Liu X, Wang M, et al. The effects of bariatric procedures versus medical therapy for obese patients with type 2 diabetes: meta-analysis of randomized controlled trials. Biomed Res Int. 2013;2013:410609. [pmid: 23971035].
Han S, Iglay K, Davies MJ, et al. Glycemic effectiveness and medication adherence with fixed-dose combination or coadministered dual therapy of antihyperglycemic regimens: a meta-analysis. Curr Med Res Opin. 2012;28(6):969-77. [pmid: 22494018].
*He S Tang YH Zhao G Pioglitazone prescription increases risk of bladder cancer in patients with type 2 diabetes: an updated meta-analysis Tumour Biol 2014 35 3 2095 102 24092576
Hemmingsen B, Christensen LL, Wetterslev J, et al. Comparison of metformin and insulin versus insulin alone for type 2 diabetes: systematic review of randomised clinical trials with meta-analyses and trial sequential analyses. Bmj. 2012;344:e1771. [pmid: 22517929].
Hemmingsen B, Schroll JB, Lund SS, et al. Sulphonylurea monotherapy for patients with type 2 diabetes mellitus. Cochrane Database Syst Rev. 2013;4. Cd009008. [pmid: 23633364].
Hernandez AV, Usmani A, Rajamanickam A, et al. Thiazolidinediones and risk of heart failure in patients with or at high risk of type 2 diabetes mellitus: a meta-analysis and meta-regression analysis of placebo-controlled randomized clinical trials. Am J Cardiovasc Drugs. 2011;11(2):115-28. [pmid: 21294599].
Home PD, Fritsche A, Schinzel S, et al. Meta-analysis of individual patient data to assess the risk of hypoglycaemia in people with type 2 diabetes using NPH insulin or insulin glargine. Diabetes Obes Metab. 2010;12(9):772-9. [pmid: 20649629].
Hovanec N, Sawant A, Overend TJ, et al. Resistance training and older adults with type 2 diabetes mellitus: strength of the evidence. J Aging Res. 2012;2012:284635. [pmid: 22988507].
Janghorbani M, Dehghani M, Salehi-Marzijarani M. Systematic review and meta-analysis of insulin therapy and risk of cancer. Horm Cancer. 2012;3(4):137-46. [pmid: 22528451].
*Johansen OE Neubacher D von Eynatten M Cardiovascular safety with linagliptin in patients with type 2 diabetes mellitus: a pre-specified, prospective, and adjudicated meta-analysis of a phase 3 programme Cardiovasc Diabetol 2012 11 3 22234149
Karagiannis T, Paschos P, Paletas K, et al. Dipeptidyl peptidase-4 inhibitors for treatment of type 2 diabetes mellitus in the clinical setting: systematic review and meta-analysis. Bmj. 2012;344:e1369. [pmid: 22411919].
Kawalec P, Mikrut A, Lopuch S. The safety of dipeptidyl peptidase-4 (DPP-4) inhibitors or sodium-glucose cotransporter 2 (SGLT-2) inhibitors added to metformin background therapy in patients with type 2 diabetes mellitus: a systematic review and meta-analysis. Diabetes Metab Res Rev. 2014;30(4):269-83. [pmid: 24829965].
*Kramer CK Zinman B Retnakaran R Short-term intensive insulin therapy in type 2 diabetes mellitus: a systematic review and meta-analysis Lancet Diabetes Endocrinol 2013 1 1 28 34 24622264
*Lamanna C Monami M Marchionni N Effect of metformin on cardiovascular events and mortality: a meta-analysis of randomized clinical trials Diabetes Obes Metab 2011 13 3 221 8 21205121
*Lapane KL Yang S Brown MJ Sulfonylureas and risk of falls and fractures: a systematic review Drugs Aging 2013 30 7 527 47 23609875
Lee MS, Choi TY, Lim HJ, et al. Tai chi for management of type 2 diabetes mellitus: a systematic review. Chin J Integr Med. 2011;17(10):789-93. [pmid: 21805298].
Lee NJ, Norris SL, Thakurta S. Efficacy and harms of the hypoglycemic agent pramlintide in diabetes mellitus. Ann Fam Med. 2010;8(6):542-9. [pmid: 21060125].
Li C, Xia J, Zhang G, et al. Nateglinide versus repaglinide for type 2 diabetes mellitus in China. Acta Diabetol. 2009;46(4):325-33. [pmid: 19183841].
Li JF, Lai DD, Ni B, et al. Comparison of laparoscopic Roux-en-Y gastric bypass with laparoscopic sleeve gastrectomy for morbid obesity or type 2 diabetes mellitus: a meta-analysis of randomized controlled trials. Can J Surg. 2013;56(6):E158-64. [pmid: 24284156].
Li L, Shen J, Bala MM, et al. Incretin treatment and risk of pancreatitis in patients with type 2 diabetes mellitus: systematic review and meta-analysis of randomised and non-randomised studies. Bmj. 2014;348:g2366. [pmid: 24736555].
Li Q, Chen L, Yang Z, et al. Metabolic effects of bariatric surgery in type 2 diabetic patients with body mass index < 35 kg/m2. Diabetes Obes Metab. 2012;14(3):262-70. [pmid: 22051116].
Liang X, Wang Q, Yang X, et al. Effect of mobile phone intervention for diabetes on glycaemic control: a meta-analysis. Diabet Med. 2011;28(4):455-63. [pmid: 21392066].
Liu Q, Li S, Quan H, Li J. Vitamin B12 status in metformin treated patients: systematic review. PLoS One. 2014;9(6):e100379. [pmid: 24959880].
Liu SC, Tu YK, Chien MN, et al. Effect of antidiabetic agents added to metformin on glycaemic control, hypoglycaemia and weight change in patients with type 2 diabetes: a network meta-analysis. Diabetes Obes Metab. 2012;14(9):810-20. [pmid: 22486990].
Loke YK, Kwok CS, Singh S. Comparative cardiovascular effects of thiazolidinediones: systematic review and meta-analysis of observational studies. Bmj. 2011;342:d1309. [pmid: 21415101].
MacLeod SF, Terada T, Chahal BS, et al. Exercise lowers postprandial glucose but not fasting glucose in type 2 diabetes: a meta-analysis of studies using continuous glucose monitoring. Diabetes Metab Res Rev. 2013;29(8):593-603. [pmid: 24038928].
Mannucci E, Monami M, Lamanna C, et al. Prevention of cardiovascular disease through glycemic control in type 2 diabetes: a meta-analysis of randomized clinical trials. Nutr Metab Cardiovasc Dis. 2009;19(9):604-12. [pmid: 19427768].
McGinley SK, Armstrong MJ, Boule NG, et al. Effects of exercise training using resistance bands on glycaemic control and strength in type 2 diabetes mellitus: a meta-analysis of randomised controlled trials. Acta Diabetol. 2014. [pmid: 24845604].
McIntosh B, Cameron C, Singh SR, et al. Choice of therapy in patients with type 2 diabetes inadequately controlled with metformin and a sulphonylurea: a systematic review and mixed-treatment comparison meta-analysis. Open Med. 2012;6(2):e62-74. [pmid: 23696771].
Monami M, Dicembrini I, Antenore A, Mannucci E. Dipeptidyl peptidase-4 inhibitors and bone fractures: a meta-analysis of randomized clinical trials. Diabetes Care. 2011;34(11):2474-2476. [pmid: 22025784].
Monami M, Ahren B, Dicembrini I, et al. Dipeptidyl peptidase-4 inhibitors and cardiovascular risk: a meta-analysis of randomized clinical trials. Diabetes Obes Metab. 2013;15(2):112-20. [pmid: 22925682].
Monami M, Dicembrini I, Mannucci E. Thiazolidinediones and cancer: results of a meta-analysis of randomized clinical trials. Acta Diabetol. 2014;51(1):91-101. [pmid: 23851465].
Monami M, Dicembrini I, Nardini C, et al. Effects of glucagon-like peptide-1 receptor agonists on cardiovascular risk: a meta-analysis of randomized clinical trials. Diabetes Obes Metab. 2014;16(1):38-47. [pmid: 23829656].
Monami M, Nardini C, Mannucci E. Efficacy and safety of sodium glucose co-transport-2 inhibitors in type 2 diabetes: a meta-analysis of randomized clinical trials. Diabetes Obes Metab. 2014;16(5):457-66. [pmid: 24320621].
Musso G, Gambino R, Cassader M, et al. A novel approach to control hyperglycemia in type 2 diabetes: sodium glucose co-transport (SGLT) inhibitors: systematic review and meta-analysis of randomized trials. Ann Med. 2012;44(4):375-93. [pmid: 21495788].
Niafar M, Hai F, Porhomayon J, Nader ND. The role of metformin on vitamin B12 deficiency: a meta-analysis review. Intern Emerg Med. 2015;10(1):93-102. [pmid: 25502588].
Oliveira C, Simoes M, Carvalho J, et al. Combined exercise for people with type 2 diabetes mellitus: a systematic review. Diabetes Res Clin Pract. 2012;98(2):187-98. [pmid: 22981711].
*Parikh M Issa R Vieira D Role of bariatric surgery as treatment for type 2 diabetes in patients who do not meet current NIH criteria: a systematic review and meta-analysis J Am Coll Surg 2013 217 3 527 32 23890843
Phung OJ, Scholle JM, Talwar M, et al. Effect of noninsulin antidiabetic drugs added to metformin therapy on glycemic control, weight gain, and hypoglycemia in type 2 diabetes. Jama. 2010;303(14):1410-8. [pmid: 20388897].
Phung OJ, Schwartzman E, Allen RW, et al. Sulphonylureas and risk of cardiovascular disease: systematic review and meta-analysis. Diabet Med. 2013;30(10):1160-71. [pmid: 23663156].
Phung OJ, Sobieraj DM, Engel SS, et al. Early combination therapy for the treatment of type 2 diabetes mellitus: systematic review and meta-analysis. Diabetes Obes Metab. 2014;16(5):410-7. [pmid: 24205921].
Picot J, Jones J, Colquitt JL, et al. Weight loss surgery for mild to moderate obesity: a systematic review and economic evaluation. Obes Surg. 2012;22(9):1496-506. [pmid: 22926715].
Poolsup N, Suksomboon N, Setwiwattanakul W. Efficacy of various antidiabetic agents as add-on treatments to metformin in type 2 diabetes mellitus: systematic review and meta-analysis. ISRN Endocrinol. 2012;2012:798146. [pmid: 22619731].
Ribaric G, Buchwald JN, McGlennon TW. Diabetes and weight in comparative studies of bariatric surgery vs conventional medical therapy: a systematic review and meta-analysis. Obes Surg. 2014;24(3):437-55. [pmid: 24374842].
Ricci-Cabello I, Ruiz-Perez I, Rojas-Garcia A, et al. Improving diabetes care in rural areas: a systematic review and meta-analysis of quality improvement interventions in OECD countries. PLoS One. 2013;8(12):e84464. [pmid: 24367662].
Rizos EC, Ntzani EE, Papanas N, et al. Combination therapies of DPP4 inhibitors and GLP1 analogues with insulin in type 2 diabetic patients: a systematic review. Curr Vasc Pharmacol. 2013;11(6):992-1000. [pmid: 22724475].
Salpeter SR, Greyber E, Pasternak GA, et al. Risk of fatal and nonfatal lactic acidosis with metformin use in type 2 diabetes mellitus. Cochrane Database Syst Rev. 2010;(1). Cd002967. [pmid: 20091535].
Schellenberg ES, Dryden DM, Vandermeer B, et al. Lifestyle interventions for patients with and at risk for type 2 diabetes: a systematic review and meta-analysis. Ann Intern Med. 2013;159(8):543-51. [pmid: 24126648].
Schopman JE, Simon AC, Hoefnagel SJ, et al. The incidence of mild and severe hypoglycaemia in patients with type 2 diabetes mellitus treated with sulfonylureas: a systematic review and meta-analysis. Diabetes Metab Res Rev. 2014;30(1):11-22. [pmid: 24030920].
*Schweizer A Dejager S Foley JE Assessing the cardio-cerebrovascular safety of vildagliptin: meta-analysis of adjudicated events from a large Phase III type 2 diabetes population Diabetes Obes Metab 2010 12 6 485 94 20518804
Schwingshackl L, Hoffmann G. Comparison of the long-term effects of high-fat v. low-fat diet consumption on cardiometabolic risk factors in subjects with abnormal glucose metabolism: a systematic review and meta-analysis. Br J Nutr. 2014;111(12):2047-58. [pmid: 24666665].
Schwingshackl L, Missbach B, Dias S, et al. Impact of different training modalities on glycaemic control and blood lipids in patients with type 2 diabetes: a systematic review and network meta-analysis. Diabetologia. 2014;57(9):1789-97. [pmid: 24996616].
Sherifali D, Nerenberg K, Pullenayegum E, et al. The effect of oral antidiabetic agents on A1C levels: a systematic review and meta-analysis. Diabetes Care. 2010;33(8):1859-64. [pmid: 20484130].
Shyangdan DS, Royle P, Clar C, et al. Glucagon-like peptide analogues for type 2 diabetes mellitus. Cochrane Database Syst Rev. 2011;(10). Cd006423. [pmid: 21975753].
Singh S, Singh H, Singh PP, et al. Antidiabetic medications and the risk of colorectal cancer in patients with diabetes mellitus: a systematic review and meta-analysis. Cancer Epidemiol Biomarkers Prev. 2013;22(12):2258-68. [pmid: 24042261].
Singh S, Singh PP, Singh AG, et al. Anti-diabetic medications and the risk of hepatocellular cancer: a systematic review and meta-analysis. Am J Gastroenterol. 2013;108(6):881-91. quiz 892. [pmid: 23381014].
Singh-Franco D, Perez A, Harrington C. The effect of pramlintide acetate on glycemic control and weight in patients with type 2 diabetes mellitus and in obese patients without diabetes: a systematic review and meta-analysis. Diabetes Obes Metab. 2011;13(2):169-80. [pmid: 21199269].
Soranna D, Scotti L, Zambon A, et al. Cancer risk associated with use of metformin and sulfonylurea in type 2 diabetes: a meta-analysis. Oncologist. 2012;17(6):813-822. [pmid: 22643536].
Strasser B, Siebert U, Schobersberger W. Resistance training in the treatment of the metabolic syndrome: a systematic review and meta-analysis of the effect of resistance training on metabolic clustering in patients with abnormal glucose metabolism. Sports Med. 2010;40(5):397-415. [pmid: 20433212].
Sun YN, Zhou Y, Chen X, et al. The efficacy of dapagliflozin combined with hypoglycaemic drugs in treating type 2 diabetes mellitus: meta-analysis of randomised controlled trials. BMJ Open. 2014;4(4):e004619. [pmid: 24710132].
Thakkar B, Aronis KN, Vamvini MT, et al. Metformin and sulfonylureas in relation to cancer risk in type II diabetes patients: a meta-analysis using primary data of published studies. Metabolism. 2013;62(7):922-34. [pmid: 23419783].
Tieu J, Coat S, Hague W, et al. Oral anti-diabetic agents for women with pre-existing diabetes mellitus/impaired glucose tolerance or previous gestational diabetes mellitus. Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2010.
Umpierre D, Ribeiro PA, Schaan BD, et al. Volume of supervised exercise training impacts glycaemic control in patients with type 2 diabetes: a systematic review with meta-regression analysis. Diabetologia. 2013;56(2):242-51. [pmid: 23160642].
Vaes AW, Cheung A, Atakhorrami M, et al. Effect of ‘activity monitor-based’ counseling on physical activity and health-related outcomes in patients with chronic diseases: A systematic review and meta-analysis. Ann Med. 2013;45(5-6):397-412. [pmid: 23952917].
van Vugt M, de Wit M, Cleijne WH, et al. Use of behavioral change techniques in web-based self-management programs for type 2 diabetes patients: systematic review. J Med Internet Res. 2013;15(12):e279. [pmid: 24334230].
Varas-Lorenzo C, Margulis AV, Pladevall M, et al. The risk of heart failure associated with the use of noninsulin blood glucose-lowering drugs: systematic review and meta-analysis of published observational studies. BMC Cardiovasc Disord. 2014;14:129. [pmid: 25260374].
Vilsboll T, Christensen M, Junker AE, et al. Effects of glucagon-like peptide-1 receptor agonists on weight loss: systematic review and meta-analyses of randomised controlled trials. Bmj. 2012;344:d7771. [pmid: 22236411].
*Wang GF Yan YX Xu N Predictive Factors of Type 2 Diabetes Mellitus Remission Following Bariatric Surgery: a Meta-analysis Obes Surg 2015 25 2 199 208 25103403
Wang S, Li P, Sun XF, et al. Comparison between laparoscopic sleeve gastrectomy and laparoscopic adjustable gastric banding for morbid obesity: a meta-analysis. Obes Surg. 2013;23(7):980-6. [pmid: 23604584].
Wang Z, Lai ST, Xie L, et al. Metformin is associated with reduced risk of pancreatic cancer in patients with type 2 diabetes mellitus: a systematic review and meta-analysis. Diabetes Res Clin Pract. 2014;106(1):19-26. [pmid: 24837144].
Waugh N, Cummins E, Royle P, et al. Newer agents for blood glucose control in type 2 diabetes: systematic review and economic evaluation. Health Technol Assess. 2010;14(36):1-248. [pmid: 20646668].
Wu Y, Liu HB, Shi XF, et al. Conventional hypoglycaemic agents and the risk of lung cancer in patients with diabetes: a meta-analysis. PLoS One. 2014;9(6):e99577. [pmid: 24924771].
Yan JH, Gu WJ, Pan L. Lack of evidence on Tai Chi-related effects in patients with type 2 diabetes mellitus: a meta-analysis. Exp Clin Endocrinol Diabetes. 2013;121(5):266-71. [pmid: 23450333].
Yang Z, Scott CA, Mao C, et al. Resistance exercise versus aerobic exercise for type 2 diabetes: a systematic review and meta-analysis. Sports Med. 2014;44(4):487-99. [pmid: 24297743].
Yin J, Deng H, Qin S, et al. Comparison of repaglinide and metformin versus metformin alone for type 2 diabetes: a meta-analysis of randomized controlled trials. Diabetes Res Clin Pract. 2014;105(3):e10-5. [pmid: 25005849].
Yip S, Plank LD, Murphy R. Gastric bypass and sleeve gastrectomy for type 2 diabetes: a systematic review and meta-analysis of outcomes. Obes Surg. 2013;23(12):1994-2003. [pmid: 23955521].
Zhang F, Xiang H, Fan Y, et al. The effects of sulfonylureas plus metformin on lipids, blood pressure, and adverse events in type 2 diabetes: a meta-analysis of randomized controlled trials. Endocrine. 2013;44(3):648-58. [pmid: 23657947].
Zhang Q, Dou J, Lu J. Combinational therapy with metformin and sodium-glucose cotransporter inhibitors in management of type 2 diabetes: systematic review and meta-analyses. Diabetes Res Clin Pract. 2014;105(3):313-21. [pmid: 25015317].
Zhang Y, Hong J, Chi J, et al. Head-to-head comparison of dipeptidyl peptidase-IV inhibitors and sulfonylureas - a meta-analysis from randomized clinical trials. Diabetes Metab Res Rev. 2014;30(3):241-56. [pmid: 24123720].
Zhou J, Zhang L, Liu H, et al. Tai Chi for type 2 diabetes mellitus. Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2012.
Zhu Z, Shen Z, Lu Y, Zhong S, Xu C. Increased risk of bladder cancer with pioglitazone therapy in patients with diabetes: a meta-analysis. Diabetes Res Clin Pract. 2012;98(1):159-163. [pmid: 22705039].
Zintzaras E, Miligkos M, Ziakas P, et al. Assessment of the relative effectiveness and tolerability of treatments of type 2 diabetes mellitus: a network meta-analysis. Clin Ther. 2014;36(10):1443-53.e9. [pmid: 25109773].

## Chronic Pain (68)

Avouac J, Vicaut E, Bardin T, Richette P. Efficacy of joint lavage in knee osteoarthritis: meta-analysis of randomized controlled studies. Rheumatology. (Oxford). 2010;49(2):334-340. [pmid: 19955221].
Bannuru RR, Natov NS, Dasi UR, et al. Therapeutic trajectory following intra-articular hyaluronic acid injection in knee osteoarthritis--meta-analysis. Osteoarthritis Cartilage. 2011;19(6):611-9. [pmid: 21443958].
Bernardy K, Fuber N, Kollner V, et al. Efficacy of cognitive-behavioral therapies in fibromyalgia syndrome - a systematic review and metaanalysis of randomized controlled trials. J Rheumatol. 2010;37(10):1991-2005. [pmid: 20682676].
Bernardy K, Klose P, Busch AJ, et al. Cognitive behavioural therapies for fibromyalgia. Cochrane Database Syst Rev. 2013;9. Cd009796. [pmid: 24018611].
Bidonde J, Busch AJ, Webber SC, et al. Aquatic exercise training for fibromyalgia. Cochrane Database Syst Rev. 2014;10. Cd011336. [pmid: 25350761].
Busch AJ, Webber SC, Richards RS, et al. Resistance exercise training for fibromyalgia. Cochrane Database Syst Rev. 2013;12. Cd010884. [pmid: 24362925].
Cao H, Li X, Han M, et al. Acupoint stimulation for fibromyalgia: a systematic review of randomized controlled trials. Evid Based Complement Alternat Med. 2013;2013:362831. [pmid: 24454493].
Cao H, Liu J, Lewith GT. Traditional Chinese Medicine for treatment of fibromyalgia: a systematic review of randomized controlled trials. J Altern Complement Med. 2010;16(4):397-409. [pmid: 20423209].
*Cawston H Davie A Paget MA Efficacy of duloxetine versus alternative oral therapies: an indirect comparison of randomised clinical trials in chronic low back pain Eur Spine J 2013 22 9 1996 2009 23686477
Chou R, Atlas SJ, Stanos SP, Rosenquist RW. Nonsurgical interventional therapies for low back pain: a review of the evidence for an American Pain Society clinical practice guideline. Spine (Phila Pa 1976). 2009;34(10):1078-1093. [pmid: 19363456].
Choy E, Marshall D, Gabriel ZL, et al. A systematic review and mixed treatment comparison of the efficacy of pharmacological treatments for fibromyalgia. Semin Arthritis Rheum. 2011;41(3):335-45.e6. [pmid: 21868065].
Clarke CL, Ryan CG, Martin DJ. Pain neurophysiology education for the management of individuals with chronic low back pain: systematic review and meta-analysis. Man Ther. 2011;16(6):544-9. [pmid: 21705261].
Cramer H, Lauche R, Haller H, et al. A systematic review and meta-analysis of yoga for low back pain. Clin J Pain. 2013;29(5):450-60. [pmid: 23246998].
Deare JC, Zheng Z, Xue CC, et al. Acupuncture for treating fibromyalgia. Cochrane Database Syst Rev. 2013;5. Cd007070. [pmid: 23728665].
Derry S, Gill D, Phillips T, et al. Milnacipran for neuropathic pain and fibromyalgia in adults. Cochrane Database Syst Rev. 2012;3. Cd008244. [pmid: 22419330].
Derry S, Moore RA, Rabbie R. Topical NSAIDs for chronic musculoskeletal pain in adults. Cochrane Database Syst Rev. 2012;9. Cd007400. [pmid: 22972108].
Ernst E. Chiropractic treatment for fibromyalgia: a systematic review. Clin Rheumatol. 2009;28(10):1175-8. [pmid: 19544042].
Falco FJ, Manchikanti L, Datta S, et al. An update of the effectiveness of therapeutic lumbar facet joint interventions. Pain Physician. 2012;15(6):E909-53. [pmid: 23159980].
Ferreira ML, Smeets RJ, Kamper SJ, et al. Can we explain heterogeneity among randomized clinical trials of exercise for chronic back pain? A meta-regression analysis of randomized controlled trials. Phys Ther. 2010;90(10):1383-403. [pmid: 20671101].
Fersum KV, Dankaerts W, O'Sullivan PB, et al. Integration of subclassification strategies in randomised controlled clinical trials evaluating manual therapy treatment and exercise therapy for non-specific chronic low back pain: a systematic review. Br J Sports Med. 2010;44(14):1054-62. [pmid: 19996331].
Fransen M, McConnell S, Harmer AR, et al. Exercise for osteoarthritis of the knee. Cochrane Database Syst Rev. 2015;1. Cd004376. [pmid: 25569281].
Glombiewski JA, Bernardy K, Hauser W. Efficacy of EMG- and EEG-Biofeedback in Fibromyalgia Syndrome: A Meta-Analysis and a Systematic Review of Randomized Controlled Trials. Evid Based Complement Alternat Med. 2013;2013:962741. [pmid: 24082911].
Glombiewski JA, Sawyer AT, Gutermann J, et al. Psychological treatments for fibromyalgia: a meta-analysis. Pain. 2010;151(2):280-95. [pmid: 20727679].
Hauser W, Klose P, Langhorst J, et al. Efficacy of different types of aerobic exercise in fibromyalgia syndrome: a systematic review and meta-analysis of randomised controlled trials. Arthritis Res Ther. 2010;12(3):R79. [pmid: 20459730].
Hauser W, Petzke F, Sommer C. Comparative efficacy and harms of duloxetine, milnacipran, and pregabalin in fibromyalgia syndrome. J Pain. 2010;11(6):505-21. [pmid: 20418173].
Hauser W, Petzke F, Uceyler N, et al. Comparative efficacy and acceptability of amitriptyline, duloxetine and milnacipran in fibromyalgia syndrome: a systematic review with meta-analysis. Rheumatology (Oxford). 2011;50(3):532-43. [pmid: 21078630].
*Hauser W Urrutia G Tort S Serotonin and noradrenaline reuptake inhibitors (SNRIs) for fibromyalgia syndrome Cochrane Database Syst Rev 2013 1 Cd010292 23440848
Hauser W, Wolfe F, Tolle T, et al. The role of antidepressants in the management of fibromyalgia syndrome: a systematic review and meta-analysis. CNS Drugs. 2012;26(4):297-307. [pmid: 22452526].
Henschke N, Ostelo RW, van Tulder MW, et al. Behavioural treatment for chronic low-back pain. Cochrane Database Syst Rev. 2010;(7). Cd002014. [pmid: 20614428].
Holtzman S, Beggs RT. Yoga for chronic low back pain: a meta-analysis of randomized controlled trials. Pain Res Manag. 2013;18(5):267-72. [pmid: 23894731].
Khoshbin A, Leroux T, Wasserstein D, et al. The efficacy of platelet-rich plasma in the treatment of symptomatic knee osteoarthritis: a systematic review with quantitative synthesis. Arthroscopy. 2013;29(12):2037-2048. [pmid: 24286802].
Lam M, Galvin R, Curry P. Effectiveness of acupuncture for nonspecific chronic low back pain: a systematic review and meta-analysis. Spine (Phila Pa 1976). 2013;38(24):2124-38. [pmid: 24026151].
Langhorst J, Klose P, Dobos GJ, et al. Efficacy and safety of meditative movement therapies in fibromyalgia syndrome: a systematic review and meta-analysis of randomized controlled trials. Rheumatol Int. 2013;33(1):193-207. [pmid: 22350253].
Langhorst J, Klose P, Musial F, et al. Efficacy of acupuncture in fibromyalgia syndrome--a systematic review with a meta-analysis of controlled clinical trials. Rheumatology (Oxford). 2010;49(4):778-88. [pmid: 20100789].
Lauche R, Cramer H, Dobos G, et al. A systematic review and meta-analysis of mindfulness-based stress reduction for the fibromyalgia syndrome. J Psychosom Res. 2013;75(6):500-10. [pmid: 24290038].
Lima TB, Dias JM, Mazuquin BF, et al. The effectiveness of aquatic physical therapy in the treatment of fibromyalgia: a systematic review with meta-analysis. Clin Rehabil. 2013;27(10):892-908. [pmid: 23818412].
Lunn MP, Hughes RA, Wiffen PJ. Duloxetine for treating painful neuropathy, chronic pain or fibromyalgia. Cochrane Database Syst Rev. 2014;1. Cd007115. [pmid: 24385423].
Meng XG, Yue SW. Efficacy of Aerobic Exercise for Treatment of Chronic Low Back Pain: A Meta-Analysis. Am J Phys Med Rehabil. 2014. [pmid: 25299528].
Mist SD, Firestone KA, Jones KD. Complementary and alternative exercise for fibromyalgia: a meta-analysis. J Pain Res. 2013;6:247-60. [pmid: 23569397].
Miyamoto GC, Costa LO, Cabral CM. Efficacy of the Pilates method for pain and disability in patients with chronic nonspecific low back pain: a systematic review with meta-analysis. Braz J Phys Ther. 2013;17(6):517-32. [pmid: 24346291].
Moore RA, Derry S, Aldington D, et al. Amitriptyline for neuropathic pain and fibromyalgia in adults. Cochrane Database Syst Rev. 2012;12. Cd008242. [pmid: 23235657].
Moore RA, Straube S, Wiffen Philip J, et al. Pregabalin for acute and chronic pain in adults. Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2009.
Moore RA, Wiffen PJ, Derry S, et al. Gabapentin for chronic neuropathic pain and fibromyalgia in adults. Cochrane Database Syst Rev. 2014;4. Cd007938. [pmid: 24771480].
Nuesch E, Hauser W, Bernardy K, et al. Comparative efficacy of pharmacological and non-pharmacological interventions in fibromyalgia syndrome: network meta-analysis. Ann Rheum Dis. 2013;72(6):955-62. [pmid: 22739992].
Orrock PJ, Myers SP. Osteopathic intervention in chronic non-specific low back pain: a systematic review. BMC Musculoskelet Disord. 2013;14:129. [pmid: 23570655].
Parr AT, Manchikanti L, Hameed H, et al. Caudal epidural injections in the management of chronic low back pain: a systematic appraisal of the literature. Pain Physician. 2012;15(3):E159-98. [pmid: 22622911].
Pereira LM, Obara K, Dias JM, et al. Comparing the Pilates method with no exercise or lumbar stabilization for pain and functionality in patients with chronic low back pain: systematic review and meta-analysis. Clin Rehabil. 2012;26(1):10-20. [pmid: 21856719].
Perrot S, Russell IJ. More ubiquitous effects from non-pharmacologic than from pharmacologic treatments for fibromyalgia syndrome: a meta-analysis examining six core symptoms. Eur J Pain. 2014;18(8):1067-80. [pmid: 25139817].
Roskell NS, Beard SM, Zhao Y, et al. A meta-analysis of pain response in the treatment of fibromyalgia. Pain Pract. 2011;11(6):516-27. [pmid: 21199320].
Rubinstein SM, van Middelkoop M, Assendelft WJ, et al. Spinal manipulative therapy for chronic low-back pain. Cochrane Database Syst Rev. 2011;(2). Cd008112. [pmid: 21328304].
Rubinstein SM, van Middelkoop M, Kuijpers T, et al. A systematic review on the effectiveness of complementary and alternative medicine for chronic non-specific low-back pain. Eur Spine J. 2010;19(8):1213-28. [pmid: 20229280].
Schaafsma FG, Whelan K, van der Beek AJ, et al. Physical conditioning as part of a return to work strategy to reduce sickness absence for workers with back pain. Cochrane Database Syst Rev. 2013;8. Cd001822. [pmid: 23990391].
Searle A, Spink M, Ho A, et al. Exercise interventions for the treatment of chronic low back pain: A systematic review and meta-analysis of randomised controlled trials. Clin Rehabil. 2015. [pmid: 25681408].
Smith TO, King JJ, Hing CB. The effectiveness of proprioceptive-based exercise for osteoarthritis of the knee: a systematic review and meta-analysis. Rheumatol Int. 2012;32(11):3339-3351. [pmid: 22821333].
Standaert CJ, Friedly J, Erwin MW, et al. Comparative effectiveness of exercise, acupuncture, and spinal manipulation for low back pain. Spine (Phila Pa 1976). 2011;36(21 Suppl):S120-30. [pmid: 21952184].
Straube S, Derry S, Moore RA, et al. Pregabalin in fibromyalgia: meta-analysis of efficacy and safety from company clinical trial reports. Rheumatology (Oxford). 2010;49(4):706-15. [pmid: 20056767].
Tzellos TG, Toulis KA, Goulis DG, et al. Gabapentin and pregabalin in the treatment of fibromyalgia: a systematic review and a meta-analysis. J Clin Pharm Ther. 2010;35(6):639-56. [pmid: 21054455].
Uceyler N, Sommer C, Walitt B, et al. Anticonvulsants for fibromyalgia. Cochrane Database Syst Rev. 2013;10. Cd010782. [pmid: 24129853].
van Middelkoop M, Rubinstein SM, Kuijpers T, et al. A systematic review on the effectiveness of physical and rehabilitation interventions for chronic non-specific low back pain. Eur Spine J. 2011;20(1):19-39. [pmid: 20640863].
Veehof MM, Oskam MJ, Schreurs KM, et al. Acceptance-based interventions for the treatment of chronic pain: a systematic review and meta-analysis. Pain. 2011;152(3):533-42. [pmid: 21251756].
Vickers AJ, Cronin AM, Maschino AC, et al. Acupuncture for chronic pain: individual patient data meta-analysis. Arch Intern Med. 2012;172(19):1444-53. [pmid: 22965186].
Wallis JA, Taylor NF. Pre-operative interventions (non-surgical and non-pharmacological) for patients with hip or knee osteoarthritis awaiting joint replacement surgery--a systematic review and meta-analysis. Osteoarthritis Cartilage. 2011;19(12):1381-1395. [pmid: 21959097].
Wang XQ, Zheng JJ, Yu ZW, et al. A meta-analysis of core stability exercise versus general exercise for chronic low back pain. PLoS One. 2012;7(12):e52082. [pmid: 23284879].
Ward L, Stebbings S, Cherkin D, et al. Yoga for functional ability, pain and psychosocial outcomes in musculoskeletal conditions: a systematic review and meta-analysis. Musculoskeletal Care. 2013;11(4):203-17. [pmid: 23300142].
*Waterschoot FP Dijkstra PU Hollak N Dose or content? Effectiveness of pain rehabilitation programs for patients with chronic low back pain: a systematic review Pain 2014 155 1 179 89 24135435
Wells C, Kolt GS, Marshall P, et al. The effectiveness of Pilates exercise in people with chronic low back pain: a systematic review. PLoS One. 2014;9(7):e100402. [pmid: 24984069].
Xu M, Yan S, Yin X, et al. Acupuncture for chronic low back pain in long-term follow-up: a meta-analysis of 13 randomized controlled trials. Am J Chin Med. 2013;41(1):1-19. [pmid: 23336503].
Yang B, Yi G, Hong W, et al. Efficacy of acupuncture on fibromyalgia syndrome: a meta-analysis. J Tradit Chin Med. 2014;34(4):381-91. [pmid: 25185355].