# OVERALL EFFECTS OF SELECTED INTERVENTIONS: CHRONIC PAIN

The information provided in this appendix reflects what was reported by the authors of the original, primary publication. We have not separately assessed the article for quality or accuracy.

## Effects by Chronic Pain Condition

Chronic low back pain. Twelve reviews evaluated exercise for CLBP.127,128,130,131,133,285-291 One additional review compared acupuncture, spinal manipulation, and exercise.292 Exercise interventions included yoga and Pilates (n=6 studies),127,128,131,133,290,291 core stability, aerobic or general exercise,130,286 mixed programs,285,287-289 and nonspecific programs.292 The largest review (n=40) found that all types of exercise compared with minimal care improved pain (MD -4.83 [100-point scale], CI -9.36 to -0.30) and disability (MD -6.41, CI -9.76 to -3.05). The number of exercise sessions was significantly associated with increasing effect sizes on pain, suggesting that for each additional session, the effect size would increase by 0.13 (CI 0.02 to 0.24).288 Another review of similar size (n=39 studies) found that strength/resistance (n=11; ES: -0.50, CI -0.77 to -0.24) as well as coordination/stabilization-focused exercise programs are effective in reducing pain (n=12, ES -0.47, CI -0.77 to -0.18).285 Four reviews found moderate evidence of yoga or Pilates reducing pain over short-term, but not long-term, follow-up (largest review n=4; SMD -0.61, CI -0.97 to 0.26),127,128,131,133 while 2 reviews found no significant effect on pain or functionality (n=4) when comparing Pilates with no treatment or lumbar stabilization.290,291 Adverse events were rarely reported for exercise interventions.

Five reviews129,293-296 and one IPD meta-analysis168 evaluated either acupuncture or chiropractic manipulation compared with usual care, no treatment, or sham intervention. One additional review compared acupuncture, spinal manipulation, and exercise.292 The largest review of acupuncture (n=32 studies) reported significant reductions in self-reported pain (n=3-4; SMD -16.76 to -0.72; CI -33.33 to -0.19) and overall function (n=3-4; SMD -0.94 to -0.36; CI -1.61 to -0.04).129 However, significant, unexplained variation in treatment effects limit these findings. Another review found acupuncture to be more effective in reducing pain compared with sham acupuncture (n=5; SMD 0.20; CI 0.09 to 0.32) or no intervention (n=5; SMD 0.49; CI 0.33 to 0.64).168 The most recent large review of chiropractic manipulation (n=26 studies) reported significant but not clinically relevant effects on short-term pain relief (SMD -4.16; CI -6.97 to -1.36) and functional status (SMD -0.22; CI -0.36 to -0.07).294 Manual therapy was no more effective than sham intervention or exercise.293

Two reviews evaluated injections (one on facet joint and the other on epidural), and using qualitative synthesis, found fair evidence for reduction in pain.297,298 Complications were rare. One additional large qualitative review examined multiple nonsurgical interventional therapies for low back pain, finding that epidural steroid injections were moderately effective for short-term but not long-term symptom relief. There was insufficient evidence for other interventional therapies for chronic low back pain, including facet joint injection and intradiscal steroid injection.299 Sex effects were not examined in any review.

One Cochrane review evaluated 30 trials of behavioral therapy compared with waitlist or usual care controls for CLBP.173 Operant behavior therapy was more effective than waitlist control (n=3; SMD -0.43, CI -0.75 to -0.11), and behavioral treatment was more effective than usual care for short-term pain relief (n=2; MD -5.18, CI -9.79 to -0.57). This review did not examine sex effects. Another review300 that evaluated many types of interventions (n=70) examined 21 behavioral studies and agreed with the conclusions of the Cochrane review. One review tested neurophysiological education only, but did not find clinically significant changes.301

One industry-sponsored review of medications, using indirect meta-analysis, evaluated serotonin norepinephrine reuptake inhibitors (SNRIs) and SSRIs compared with NSAIDs, tramadol, and narcotics and found that, compared with placebo, scheduled opioids were most effective in reducing pain (n=8; SMD -0.39, CI -0.47 to -0.31), followed by nonscheduled opioids, Cox II inhibitors, and duloxetine.126

One review of QI interventions evaluated pain rehabilitation programs compared with controls.132 This review identified 18 trials, finding a moderate effect of pain rehabilitation programs on improving disability (beta=0.429, SE=0.160, p=0.0009) and quality of life (beta=0.417, SE=0.033, p<.001).

Fibromyalgia. Of the 34 reviews of FM interventions, 11 were conducted by an organization known for high-quality reviews.134-137,141,144,147,150,153,161,302 Fourteen examined medication treatment for FM: 7 for antidepressants134-140 5 for anticonvulsant agents,137,141-144 and 2 for both classes of drugs.145,146 Of the reviews of different antidepressant drug classes, one examined a tricyclic agent,135 and 3 focused on SNRIs.134,136,137 A review that included 7 studies focusing specifically on FM found that amitriptyline reduced pain more than placebo with an RR of 2.9 (CI 1.7 to 4.9) based on 4 studies with second-tier data.135 Another review that included 10 studies focused on FM found that SNRIs, specifically duloxetine and milnacipran, had small beneficial effects on both pain with a SMD -0.23 (95% CI -0.29 to -0.18), and quality of life with a SMD of -0.20 (95% CI of -0.25 to -0.14).134 For this review of SNRIs, the intended subgroup sex effects analyses for outcome of pain were not conducted due to lack of available individual patient-level data. This same review noted no difference between placebo and SNRI with respect to serious adverse effects, though more patients withdrew for adverse events in the SNRIs arms than in the placebo arm with an RR of 1.83 (CI 1.53 to 2.18). Additional reviews that focused solely on milnacipran,137 duloxetine,136 or a mixture of SNRIs, milnacipran, SSRIs, and tricyclic antidepressants supported the above findings related to pain relief.

The anticonvulsant agents gabapentin and pregabalin were found to improve pain in 5 reviews.141-144,302 In one trial of 150 patients included in the most recent of these reviews,302 gabapentin was noted to decrease pain more than 30% from baseline at 2400mg daily versus placebo with an RR of 1.6 (CI 1.07 to 2.42). Similarly, pregabalin reduced fibromyalgia pain 50% compared with placebo (RR 1.59, CI 1.33 to 1.90) based on high-quality evidence from 5 studies including 3256 patients,141 and an RR of 1.5 to 1.7 in a second review at doses 300mg to 600mg per day.142 A dose-response relationship with pregabalin was also noted for both pain control and adverse events,142,143 which were most frequently dizziness and somnolence.142,302 Serious adverse events were not higher with anticonvulsant treatment.

We identified 6 reviews with meta-analyses that included trials of various forms of exercise as treatment for pain associated with FM.147-152 Four of 5 types of exercise were found to decrease pain when compared with placebo, but it is less clear if any types of exercise are superior compared with other forms of exercise. Specifically, low- to moderate-quality evidence from 7 studies suggests that supervised aquatic exercise training causes moderate decreases in pain with an MD of -6.59 (CI -10.71 to -2.48) on a 100-point scale; but this review did not find a significant improvement in pain compared with land-based exercise.147 Another review152 also found improvement with aquatic therapy, especially if the duration was at least 20 weeks. Aerobic exercise was also found to lead to significant reductions in pain with an SMD of -0.31 (CI -0.46 to -0.17).148 In a multiple treatment comparison analysis, low-quality evidence suggests that moderate to high-intensity resistance exercise training reduces pain in FM.150 Adverse effects related to aerobic exercise were infrequent.148

Results for meditative movement therapies (MMT) such as yoga, tai chi, and qigong were conflicting. One review evaluating 7 studies found that these therapies did not reduce pain but may improve health-related quality of life.149 Another review found a medium-to-high effect size for MMT based on weak data.151 In both reviews, MMT was found to be safe with a low rate of dropout due to adverse events in one review149 and no serious adverse events in the second.151

Six reviews examined different types of behavioral interventions.153-158 One review of 21 studies conducted in adults with FM found low-quality evidence that CBT compared with control produced an end-of-treatment benefit of 0.5 points on a scale from 0 to 10 with respect to pain (SMD -0.27, CI -0.47 to -0.07) and a benefit of 0.7 points for reducing disability (SMD -0.30, CI -0.51 to -0.08).153 Another review of 23 studies found that CBT produced a moderate positive effect on pain (n=8; Hedge's g 0.60, CI +0.43 to +0.76). Psychological treatments other than CBT had a smaller effect size (n=18; Hedge's g 0.27, CI +0.17 to +0.37)158 Mindfulness-based stress reduction also led to a small beneficial effect on FM-related pain155,156 and quality of life,155 based on generally low-quality evidence. The same was true of electromyogram-based biofeedback, but not electroencephalogram-based biofeedback.157 No specific information was noted about adverse events.

Five reviews examined acupoint stimulation/acupuncture for FM159-163 and came to similar conclusions. These reviews included from 9 to 16 RCTs. Compared with sham acupuncture, acupuncture did not significantly reduce FM-related pain. Based on one RCT with 16 participants, acupuncture did appear to be more effective than no treatment with an RR of -30.19% (CI -55.23% to -5.15%) and more effective as an adjunct to standard therapy based on one RCT with 58 patients with an RR of -37.50% (CI -48.75% to -26.25%).161 There was some low-quality evidence that acupuncture is more effective at reducing pain than medications.159-161 Electro-acupuncture may be better than manual acupuncture at pain reduction.161 That review concluded there is insufficient information about adverse events to draw definitive conclusions; however, another review162 reported adverse effects from 8 of 25 studies as bruising, nausea, fainting, discomfort with needles, and temporary edema of the hand. One trial reported that a patient had mild scalding on the skin after being included in a cupping group. One review examined 4 studies of chiropractic care for FM and concluded that there was no significant difference between intervention and control groups.164

Knee OA. We identified 8 reviews that examined intervention effects on pain due to knee OA.165-172 One large review evaluating 54 trials found high-quality evidence that land-based therapeutic exercise significantly reduced pain compared with control (nonexercise or nontreatment) with an SMD -0.49 (CI -0.39 to -0.59).167 Eight studies included measurement of serious adverse events, and none were reported. Similar, a review of pre-operative interventions included 4 trials which found that exercise programs significantly decreased pain from knee OA with a SMD -0.43 (CI -0.13 to 0.73).170 One review of 7 trials of proprioceptive-based exercise found no improvement in pain and a small improvement in function.303

One review of medications used a multiple treatment comparison meta-analysis to examine the effects of topical NSAIDs for pain in patients with chronic musculoskeletal pain.166 The review included 34 studies, 16 of which focused on knee OA. Topical NSAIDs were more effective than placebo (RR 1.29 for 50% pain reduction or equivalent measure; CI 1.21 to 1.38) but not more effective than oral NSAIDs for pain in the context of osteoarthritis (RR 1.02, CI 0.94 to 1.11). Topical NSAIDs led to fewer gastrointestinal side effects than oral NSAIDs but led to an increase in local adverse events (mostly skin-related). This review did not evaluate sex effects.

Three reviews examined injections for knee OA. One review165 examined the trajectory of intra-articular hyaluronic acid therapeutic effects on knee OA and found a beneficial effect on pain that peaked at 8 weeks post-injection (n=54; ES 0.46, CI 0.28 to 0.65), diminishing to a small effect at 24 weeks (ES 0.21, CI 0.10 to 0.31).One review 172 considered 4 RCTs and 2 studies that compared platelet-rich plasma (PRP) injections as compared with intra-articular normal saline or hyaluronic acid. Based on 4 studies, this review found that PRP led to greater improvements in the WOMAC, a composite score304 of pain, stiffness and function with an MD of -18.0 (-28.8 to -8.3). Of note, they report that there was an increase in nonspecific adverse events among those who received PRP versus control (8.4% vs 3.8%). A third review of 6 RCTs found no benefit of joint lavage on pain due to knee OA.169 None of these reviews evaluated sex effects.

One review using IPD meta-analysis of 31 studies examined acupuncture for chronic pain including 9 studies of knee OA.168 Acupuncture decreased pain of knee OA compared with both no acupuncture (SMD 0.57, CI 0.29 to 0.85) and sham acupuncture (SMD 0.37, CI 0.03 to 0.72). This review did not evaluate sex effects.