# OVERALL EFFECTS OF SELECTED INTERVENTIONS: TYPE 2 DIABETES

The information provided in this appendix reflects what was reported by the authors of the original, primary publication. We have not separately assessed the article for quality or accuracy.

## Effects by Interventions for Diabetes

Medications. Of 120 eligible reviews on medications, we performed full data extraction on 75, prioritizing those that evaluated multiple drug classes or addressed less frequently examined categories (eg, meglitinides), among other criteria (see Methods). Glycemic control (n=38; reviews) and weight (n=25) were the most frequently included outcomes. Cardiovascular events (n=12) and mortality (n=16) were evaluated less often. Among adverse events, hypoglycemia was the most frequently discussed (n=29). The largest review, originating from an organization known for high-quality reviews, focused on risk for lactic acidosis associated with metformin therapy and included 347 studies.78 This study evaluated 70,490 patient-years of metformin use compared with 55,451 patient-years among nonusers, with 39% of women among both users and nonusers, and found no reported cases of lactic acidosis. The upper bound for the true incidence was estimated to be 4.3 cases per 100,000 patient-years among metformin users compared with 5.4 cases for nonusers.78

The next largest review included 277 RCTs, with 46% women overall, and examined effectiveness (dichotomously defined as reaching hemoglobin A1c target or not) and risk for adverse events for multiple drug classes compared with metformin.260 This review used network meta-analysis, conducting 173 direct and 180 indirect comparisons. Most drug classes were found to improve the likelihood of achieving glycemic targets when added to existing metformin therapy, ranging from the lowest benefit for rosiglitazone (OR 1.2, CI 1.1 to 1.3) to the highest for glucagon-like peptide 1 agonists (OR 11.1, CI 3.4 to 35.9). Sulfonylureas (OR 3.95, CI 1.82 to 8.55), a-glycosidase inhibitors (OR 3.24, CI 1.69 to 6.24), and meglitinides (OR 3.25, CI 1.83 to 5.75) were all associated with increased risk for hypoglycemia when added to metformin.260

Bariatric surgery. Of 12 reviews on bariatric surgery, only 3 were restricted to RCTs.261-263 Weight loss and diabetes remission were evaluated by nearly all reviews. The 3 largest and most recent reviews included 39 studies,100 35 studies,264 and 33 studies.265 One of these reviews examined multiple surgical procedures and reported sex effects on diabetes remission (key results reported above).100 The other reviews evaluated gastric banding versus multiple comparators,264 and gastric bypass versus sleeve gastrectomy.265 Gastric banding was associated with average 47% excess weight loss over 2 years.264 There were no differences in rates of diabetes remission (67% and 81% at 3 and 36 months for gastric bypass, compared with 56% and 80% for sleeve gastrectomy) or in excess weight loss between the 2 procedures.265

Psychoeducation and mixed behavioral interventions. Six reviews investigated the effect of psychoeducation and/or mixed behavioral interventions on glycemic control (n=6 reviews) and/or weight (n=3 reviews). Included studies ranged from 13 to 33, and 4 reviews were restricted to RCTs.79,83,106,266 Three reviews reported proportion of women included in primary studies (range 45% to 70%),102,266,267 and one specifically evaluated treatment effects in minority women.102

Four reviews evaluated mixed interventions consisting of psychoeducation and exercise with or without dietary advice.79,83,102,106 The other 2 mixed interventions included mobile phone applications267 and internet-based self-management strategies.266 The largest review (n=33 studies) was conducted by the Cochrane collaboration, and examined culturally appropriate health education and exercise in ethnic minority groups in middle- and upper-income countries.83 There was high-quality evidence to support that these interventions reduced HbA1c at 6 months (n=14; MD -0.53%, CI -0.72% to -0.35%), with some sustained effect at 12 months (-0.2%) and 24 months (-0.3%). There were no statistically significant effects on body mass index. Subgroup analyses were not performed. Another review, based on a 2011 AHRQ report, inspected the progression of diabetes-related complications and found significantly decreased risks of peripheral neuropathy, nonfatal myocardial infarction, and death with lifestyle interventions at 13.3 years of follow-up.79 There were no significant differences in risk for retinopathy or nephropathy between the intervention and control groups.

One review of internet-based self-management provided qualitative results showing that psychoeducation and behavioral techniques via mobile phone applications were associated with improved HbA1c (n=10; WMD -0.81, CI -1.11% to -0.50%).267

Supervised exercise. Of 14 reviews on supervised exercise, 10 were restricted to RCTs, and the number of included studies ranged from 2 to 34. Six systematic reviews reported proportions of women in primary studies (median 53%, range 3% to 88% female), but none reported sex effects. Nearly all reviews (n=13) reported results for glycemic control, while 4 reported on weight loss,74,268-270 and 6 reported other outcomes.74,269,271-274 None reported adverse events.

Five reviews compared the effects of aerobic exercise, resistance exercise, and combinations of the 2 on HbA1c.268,269,275-277 The largest and most recent review restricted to RCTs included 26 primary studies with a minimum intervention duration of 12 weeks.276 This review found that all forms of exercise reduced HbA1c (aerobic MD -0.70%, CI -1.02% to -0.38%; resistance MD -0.62%, CI -1.14% to -0.11%; combined MD -0.47%, CI -0.64% to -0.31%) and that exercise volume (ie, frequency and duration) is a main determinant of the effect on glycemic control. However, a slightly older review that included 34 RCTs with a minimum treatment duration of 8 weeks reported that combined aerobic and resistance exercise improved glycemic control more than aerobic exercise alone (MD -0.67%, CI -0.93% to -0.40%; MD -0.60%, CI -0.98% to -0.27%, respectively).268

Five reviews investigated only resistance exercise271,274,278 or aerobic exercise alone.270,273 All reported improved HbA1c for intervention groups compared with control. Four reviews examined other specific types of exercise. Of these, 3 reviews examined tai chi,272,279,280 and one investigated yoga74; none found a statistically significant effect on glycemic index, weight, or cardiovascular risk.

Dietary interventions. Four eligible reviews on dietary interventions were restricted to RCTs and reported on both HbA1c and weight/BMI.105,281-283 Adverse events were not reported, and none reported gender distribution or sex effects. None originated from an organization known for high-quality systematic reviews. The number of trials ranged from 8 to 20.

The largest review (n=20 studies)105 examined 6-month outcomes after various dietary interventions (ie, high fiber, high protein, low carbohydrate, low glycemic index, Mediterranean, vegan, or vegetarian) compared with one of multiple control diets (ie, ADA, high glycemic index, low fat, or low protein). This review concluded that the Mediterranean diet was the most effective at decreasing HbA1c (n=3; MD -0.41%, CI -0.58% to -0.24%) while low-carbohydrate (n=7; MD -0.12%), low glycemic index (n=3; MD -0.14%), and high protein (n=2; MD -0.28%) were all more effective than diets with higher carbohydrate content. Both the Mediterranean and low carbohydrate diets produced weight loss (MD -1.84 and -0.69 kg, respectively), but the difference was statistically significant only for the Mediterranean diet.

Quality improvement. Three reviews evaluated different quality improvement strategies. None provided the gender distribution of included studies and none reported sex effects. The largest review (n=52 studies) examined the effect of care management on glycemic control.75 Statistically significant reductions in HbA1c were found (WMD -0.22%, CI -0.40% to -0.04%), but given high heterogeneity, the authors suggested these results were unlikely to be important. The second eligible review included 26 studies, which investigated 9 quality improvement strategies applied to rural settings.284 Quality improvement was more effective than control for reducing HbA1c (MD -0.41%, CI -0.75% to -0.07%), and subgroup analyses showed that using multiple strategies and a community setting for interventions were more effective compared with fewer strategies or a clinical setting, respectively. The third review (n=20 studies) was restricted to RCTs that evaluated computerized decision support systems (CDSS) in primary care.73 This qualitative synthesis reported that CDSS alone or with reminders improved process of care but did not affect health outcomes, whereas when CDSS was combined with feedback on self-management performance or case management, HbA1c improved.