# OVERALL EFFECTS OF SELECTED INTERVENTIONS: DEPRESSION

The information provided in this appendix reflects what was reported by the authors of the original, primary publication. We have not separately assessed the article for quality or accuracy.

## Effects by Diagnostic Group for Depressive Disorders

Major depressive disorder or depressive disorder. Antidepressants were evaluated using IPD meta-analysis,42-50 multiple treatment comparison meta-analysis,34,203 conventional meta-analysis,56,58,204-207 qualitatively,57 and using mixed approaches.208 A review of 165 antidepressant trials in patients with major depressive disorder found clinical response rates of 54.3% for antidepressants and 37.9% for placebo.204 The most comprehensive comparative effectiveness review (n=234 studies) used a multiple treatment comparison analysis to compare different antidepressants.34 This study, conducted by an EPC, found that antidepressants were effective and that there were no clinically important differences in efficacy or effectiveness between antidepressants for acute- or continuation-phase treatment. Subgroup analyses did not show differences in treatment effects by age, sex, ethnicity, or comorbid condition.

Five reviews evaluated antidepressants for late-life depression.34,44,45,56,208 Results were inconsistent with some reviews finding antidepressants less effective for older adults (>65 years of age) than for younger adults.44,208 Other reviews found no moderating effect of older age.34 Antidepressants were associated with decreased suicidal risk in older (≥65 years of age) and younger adults.45

Psychotherapy for depressive disorders was examined in 35 reviews.32,33,35-38,52-54,60,209-233 Reviews evaluating multiple therapies (n=92-132 included trials) found psychotherapy compared with inactive control more effective for reducing depressive symptoms (n=117; SMD 0.67, CI 0.60 to 0.75), and psychotherapy increased the proportion of patients with a clinical response or clinical remission.60,211 Therapies examined included cognitive behavioral therapy (CBT), problem-solving therapy (PST), short-term psychodynamic therapy, interpersonal therapy, behavioral activation, and nondirective counseling. However, when accounting for publication bias (SMD 0.42) or when restricting analyses to the highest quality studies (Cohen's d 0.22), effects were diminished.33,210 Effects did not differ significantly for different types of psychotherapy. Therapy was more effective than control for improving hopelessness but not suicidality.210 For major depressive disorder and subsyndromal depression, psychotherapy did not differ from antidepressant medication but was less effective than antidepressants in patients with dysthymia.37,215,228 Four reviews evaluated psychotherapy in older adults, finding the strongest evidence of efficacy for CBT (n=14; Hedges' g -0.57, CI -0.80 to -0.34).216,223,224,227

Reviews concluded that CBT is effective in individual and group formats.224,226 Four reviews evaluated computerized therapy (predominately based on CBT) compared with inactive control or treatment as usual for patients with depressive disorders.230-233 Consistent with the other reviews, the largest identified 19 RCTs and found computerized therapy effective for depressive disorders (n=19; Cohen's d -0.56, CI -0.71 to -0.41).232 An ESP review found that 6 to 8 sessions of CBT or PST improved depressive symptoms more than control (n=7; SMD -0.42, CI -0.74 to -0.10) for patients recruited from primary care settings.36 Cochrane reviews concluded that low-quality evidence suggested that third-wave therapy (eg, behavioral activation, acceptance and commitment therapy) may be effective and similar to other psychotherapies.32,35

Seven reviews evaluated a combination of antidepressants plus psychotherapy compared with one of these treatments alone for acute-phase treatment of depressive disorders.55,234-239 The largest review found greater reduction in depressive symptoms for combined treatment than for antidepressants alone (n=23; Hedges' g 0.43, CI 0.29 to 0.57).237 Another review found a small benefit from combined treatment compared with psychotherapy plus placebo pill (n=16; Cohen's d 0.25, CI 0.03 to 0.46).235

Seven reviews evaluated aerobic exercise compared with other physical activity, antidepressants, or treatment as usual.240-246 Exercise was more effective than control with effect sizes ranging from small to moderate. 243-246 Aerobic exercise was not more effective than other physical activity (n=8; SMD 0.01, CI -0.23 to 0.24) or antidepressants. 240 However, aerobic exercise improved depressive symptoms when used to augment treatment as usual (n=4; SMD -0.44, CI -0.79 to -0.09).240,241 A single review of yoga242 found evidence that yoga was more effective than usual care. These reviews did not examine sex effects.

A single IPD meta-analysis evaluated low-intensity self-help interventions for depressive disorders or mixed depression and anxiety.41 Self-help interventions were more effective than treatment as usual for reducing depressive symptoms (n=16 comparisons; SMD -0.42, CI -0.55 to -0.29). An analysis of potential moderators of intervention effects suggested that intervention effects did not vary by sex but were greater as baseline severity increased.

Three reviews evaluated quality improvement interventions that were predominately a form of collaborative care.40,59,247 The largest review247 identified 40 trials, finding moderate benefit on depressive symptoms for collaborative care compared with treatment as usual or other enhanced care (Cohen's d 0.31, CI 0.16 to 0.47).

Dysthymia/persistent depressive disorder. Six reviews evaluated interventions for dysthymia.51,55,204,248-250 A multiple treatment comparison meta-analysis found antidepressants more effective than placebo (n=45; OR for response 2.35 to 6.98 for various antidepressants).249 A conventional meta-analysis also found antidepressants more effective than placebo (n=9; RR for response 1.75, CI 1.49 to 2.04).204 There were no differences in treatment response between SSRIs and tricyclic antidepressants, but dropouts were fewer with SSRIs (n=7, RR=0.41; CI 0.19, 0.86).250 Psychotherapy was more effective than control for reducing depressive symptoms (n=8; Cohen's d 0.23, CI 0.06 to 0.41) but less effective than antidepressants (n=10, Cohen's d -0.31, CI -0.53 to -0.09).55,248 In one review, interpersonal psychotherapy plus antidepressants was more effective than antidepressants alone (OR 1.83),249 but in another review, combined treatment was not more effective than antidepressants alone for patients with chronic major depressive disorder, dysthymia, double depression, or recurrent depression (n=8; RR for response 1.20, CI 0.98 to 1.48).51 No other interventions were evaluated.

Subyndromal/minor depressive disorder. Two reviews evaluated psychotherapy in older adults with subsyndromal depression.251,252 In the larger review,252 psychotherapy, including CBT, PST, and behavioral activation, was more effective than wait-list, placebo pill, or treatment as usual controls (n=5; 701 patients; no effect estimate). A single review253 identified 8 trials evaluating antidepressants for subsyndromal depression or mild major depressive disorder. Antidepressants showed small improvements for depressive symptoms compared with placebo (n=2; MD Hamilton Depression Rating Scale -1.39, CI -2.41 to -0.36). None of these reviews evaluated sex effects, and no other interventions were evaluated.

Treatment-resistant depression. Three reviews evaluated interventions for treatment-resistant depression and found the evidence sparse.39,254,255 Mindfulness-based cognitive therapy plus treatment as usual was more effective than treatment as usual in 2 trials (MD on Beck Depression Inventory -10.28, CI -17.18 to -3.38).254 Compared with active management, an ESP review identified 2 good-quality trials that showed similar benefit from augmenting antidepressant treatment with other antidepressants or psychotherapy, or switching antidepressants.39 None of these reviews evaluated sex effects, and no other interventions were evaluated.

Relapse prevention. Seven reviews evaluated interventions for treatment-resistant depression.34,214,254,256-259 Psychotherapy alone or in combination with an antidepressant decreased the risk of relapse (n=8; RR=0.79, CI 0.66 to 0.96).258 Specific therapies that were found effective were group or individual CBT,256,258 interpersonal therapy,214 and mindfulness-based cognitive therapy.254,258,259 Antidepressants (primarily SSRIs and SNRIs) were effective in preventing relapse (n=54; OR for relapse 0.35, CI 0.32 to 0.39) in patients who had responded to an antidepressant.257 An EPC-conducted multiple treatment comparison meta-analysis found no clinically important differences in efficacy between different antidepressant medications.34 None of these reviews evaluated sex effects, and no other interventions were evaluated.