# RESPONSES TO REVIEWER COMMENTS

Mapping the Evidence: Sex Effects in High-impact Conditions for Women Veterans – Depression, Diabetes, and Chronic Pain

Question Text | Reviewer Number | Comment | Response
Are the objectives, scope, and methods for this review clearly described? | 1 | Yes | Acknowledged
Are the objectives, scope, and methods for this review clearly described?
Are the objectives, scope, and methods for this review clearly described? | 3 | Yes | Acknowledged
Are the objectives, scope, and methods for this review clearly described?
Are the objectives, scope, and methods for this review clearly described? | 4 | Yes | Acknowledged
Are the objectives, scope, and methods for this review clearly described?
Are the objectives, scope, and methods for this review clearly described? | 5 | Yes | Acknowledged
Are the objectives, scope, and methods for this review clearly described?
Are the objectives, scope, and methods for this review clearly described? | 7 | Yes | Acknowledged
Are the objectives, scope, and methods for this review clearly described?
Are the objectives, scope, and methods for this review clearly described? | 8 | Yes | Acknowledged
Is there any indication of bias in our synthesis of the evidence? | 1 | No | Acknowledged
Is there any indication of bias in our synthesis of the evidence?
Is there any indication of bias in our synthesis of the evidence? | 3 | No | Acknowledged
Is there any indication of bias in our synthesis of the evidence?
Is there any indication of bias in our synthesis of the evidence? | 4 | No | Acknowledged
Is there any indication of bias in our synthesis of the evidence?
Is there any indication of bias in our synthesis of the evidence? | 5 | No | Acknowledged
Is there any indication of bias in our synthesis of the evidence?
Is there any indication of bias in our synthesis of the evidence? | 7 | No | Acknowledged
Is there any indication of bias in our synthesis of the evidence?
Is there any indication of bias in our synthesis of the evidence? | 8 | No | Acknowledged
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 1 | No | Acknowledged
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 3 | No | Acknowledged
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 4 | Yes - It is difficult to know whether studies were overlooked, give the way results are reported in broad categories, but the evidence reviewed does not appear to be comprehensive or include the most high impact/high quality reviews available. For example, only one review of medications for low back pain is discussed (on page 22, citation 193). Other reviews of medications for back pain are available and seemingly should be included, but I can't tell if they were because the number of reviews of medications is presented for all chronic pain conditions combined. For LBP injections, 2 reviews from low tier journals are highlighted, but the high quality American Pain Society sponsored reviews of interventional therapies by Roger Chou et al (published in Journal of Pain in 2009) are not included. | We identified 3 Chou citations in the Journal of Pain during 2009. These were examined and found not eligible. However, we identified another review from this author in Spine (2009), which has been included in the final report. We also conducted a supplemental search for studies that addressed eligible interventions for chronic knee pain due to osteoarthritis. Additional eligible reviews were identified and are included in the final report. We think the relatively low number of eligible articles for chronic pain conditions is in part due to the interventions chosen for evaluation.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 5 | No | Acknowledged
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 7 | No | Acknowledged
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 8 | No | Acknowledged
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft | 1 | Methodology seems very sound - further examination of primary trials is valuable and a good plan. | Thank you.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft | 3 | Overall feedback:
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft | 3 | This review seeks to create “…an evidence map to aid prioritization and development of implementation projects and research initiatives” in order to address the emerging healthcare needs of women Veterans, which has the potential to be of great benefit to policy makers and researchers alike. Overall the manuscript flows exceedingly well and the authors present the information in a balanced, logical, thoughtful, and succinct manner. Particular strengths are the inclusiveness of the treatments types that were reviewed and the consistent organization and framing that facilitates readership from section to section. | Thank you.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft | 3 | Overall this reviewer found that the manuscript may be enhanced by some minor adjustments or additions in the following specific areas:
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft | 3 | 1. The title, “Women's Health Evidence Map”, is rather broadly worded given that the paper focuses on three health conditions (depression, DM, and chronic pain). This reviewer recommends re-working the title or adding a subtitle that speaks to the content area covered in the report. A subtitle may be particularly suitable if subsequent papers may expand the health evidence map by reviewing additional health conditions. | We agree that the title was incomplete. It has been revised to “Mapping the Evidence: Sex Effects in High-impact Conditions for Women Veterans—Depression, Diabetes, and Chronic Pain.”
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft | 3 | 2. In various locations the studies contained within are referred to descriptively as “low grade”, “low quality”, “high quality”, “good quality” and so forth. There is a paragraph within the paper that indicates that a formal assessment of methodological rigor is “beyond the scope of the project” (see Quality Assessment page 5) however subsequent use of these descriptors suggests at least informal evaluation of the papers. This reviewer suggests including a description (perhaps in the Quality Assessment section) that at least informally anchors these descriptors. In addition, would recommend standardizing the descriptors—eg, using low quality or low grade unless these two descriptors differ from one another. | We've standardized the descriptors and clarified when we are referring to a high-quality review (as defined by a Cochrane, ESP, or EPC review) versus a summary statement about the quality of the evidence made by the review authors.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft | 3 | 3. The description of the iterative process and use of stakeholders to determine the health conditions chosen left this reviewer looking for additional information. For example, what was the composition of the stakeholder group? Why only three conditions versus some other number? Did the iterative process yield agreement/ranking that only suggested review of 3 health conditions with a fourth (or fifth, etc.,) not reaching a reasonable consensus or convergence of opinion? | We've added additional detail to the methods to describe the stakeholders and the process for prioritizing the included conditions.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft | 3 | 4. Diabetes Section: page 16 the follow sentence may be improved by revising “last” to “lastly”: “Last, all 3 reviews of DPP-4 inhibitors applied IPD meta-analyses to data from industry studies.137,142,143. “ | Edit made.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft | 3 | 5. Evidence Gaps for Sex Effects Subsection: The paragraph that starts “In response to underrepresentation of women and minorities…” while containing important information, seems out of place in a summary of the evidence gaps for sex effects and more suited to the subsequent section entitled “Achieving Adequate Representation of Women in Clinical Studies”. The paragraph on “evidence gaps” may be enhanced by further description of where sex effects lead to reasonably sound information (information of use clinically) or to highlight what guidance is lacking with regard to clinical care given the very limited information regarding sex effects. | We have moved this paragraph to the recommended section. We considered the suggestion to add recommendations for clinical care. First, our goal was more descriptive. We also did not conduct a quality assessment of the systematic reviews. Furthermore, the sex results were generally small and arrived at by poorly suited analytic techniques. Thus, we do not feel confident in making specific clinical treatment recommendations. However, in order to address the clinical implications of our results, we have identified promising areas that could, with further research, lead to sex-specific clinical recommendations. In addition, we offer some discussion of how these proposed areas of research would impact clinical care for women.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft | 3 | 6. Achieving Adequate Representation of Women in Clinical Studies Subsection: It seems implicit in this paragraph that inclusion of women Veterans in research studies is somehow only available for women Veterans who are enrolled in VA care (i.e, the sentence on page 27 reads: “Inclusion of women in VA research is particularly challenging because the enrollment of women Veterans in VHA, while growing, remains a relatively low proportion (6.5% in 2012).”. One could argue that adequate representation is also hampered by only enrolling women in VA care (into studies) rather that expanding recruitment to women Veterans more broadly. In addition, adequate representation of the needs of women Veterans more broadly is also affected by only studying only/primarily women enrolled in VA care. This portion of the paper may be improved by acknowledgement of these limitations and how these limitations may affect or influence the knowledge base. | We addressed this suggestion by broadening our discussion regarding barriers to recruitment, so that we noted (1) the small proportion of total veteran population who are women and (2) general barriers found for study participation by minorities and women. Thus, while we agree that expanding to women Veterans not enrolled in VA may increase the participant pool somewhat, we think this would ultimately not make a substantial difference. Additionally, recruiting these women poses significant complications for VA-based research, given that such projects often utilize VHA resources (eg, EHR).
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft | 3 | 7. Prioritizing Areas for Evaluation of Sex Effects Subsection: most of this paragraph appears to speak to the prior sub-section content, which is Achieving Adequate Representation of Women in Clinical Studies. This reviewer suggests relocating this information to the above section and adding additional text in the Prioritizing Areas for Evaluation of Sex Effects that that includes suggestions that speak to the three content areas (depression, diabetes, chronic pain) that were so thoroughly reviewed in earlier portions of the paper. | Thank you for this comment. We've revised and expanded this section to include examples specific to conditions evaluated in the report.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft | 3 | 8. The paper would benefit from additional discussion points that address or highlight: a. Key points for care based on what is known now—as limited as that may be (perhaps in the Discussion or even more suited for the Evidence Gaps subsection on page 26) as a result of the health evidence map. Suggesting content along the lines of clinical implications. | We appreciate this suggestion but have intentionally avoided statements on clinical implications. The primary goal was to describe the volume of studies and whether sex effects have been examined. Without a careful quality assessment, we are hesitant to suggest clinical actions based on the estimates of intervention effects that we report.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft | 3 | b. Future directions/research gaps. This could be a separate section or become part of a slightly re-worked section that is currently titled: Prioritizing Areas for Evaluation of Sex Effects. The content of that “prioritizing areas” is broad and speaks to the pressing need for researchers to incorporate adequate methodology to address sex effect questions within their projects. The content I would recommend adding (here or elsewhere) are gaps within the content areas of depression, DM, and chronic pain that would provide recommendations for the scientific community on possible future directions. | Thank you for this suggestion. We've added example of gaps and types of studies that could be conducted to address these gaps for the conditions reviewed. We've also discussed the potential clinical implications of results from these proposed studies.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft | 4 | In general, I found this evidence map to be difficult to follow and to review. I believe this is attributable primarily to the enormous scope of the review. Attempting to provide brief overviews of the evidence for all of the interventions in all three huge clinical areas has resulted in extremely superficial and potentially misleading summaries of evidence for the individual interventions and conditions. The overview approach also obscures and detracts from the findings on sex effects, which is the main focus and strength of the report. (For example, the evidence for medications in chronic LBP, see specific comment below.) I think these problems could be substantially addressed by focusing just on evidence (and lack thereof) regarding sex differences. | Thank you for this comment. We agree that the scope is large and the key messages could be difficult to identify with the current report structure. Therefore, we've substantially reorganized the report to consolidate the findings on sex effects across the three conditions. We've moved the information on intervention effects in general to an Appendices (by condition), as these were not the primary focus of our evidence map.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft | 4 | Specific comments:
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft | 4 | 1. The definition and merits of individual patient data (IPD) meta-analysis should be briefly described (and citations provided) in the methods section. Also, as IPD is an unfamiliar abbreviation, it should be included in the abbreviation list and spelled out in the table footnotes. | We've added a definition for IPD meta-analysis to Table 2 (Definitions of statistical approaches) and added a brief rationale for the merits of this approach to the methods section. We've been careful to define this abbreviation when used in tables.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft | 4 | 2. The choice to limit reviews to the past 5 years may create an unintended bias for lower quality reviews in fields with few large funded RCTs (such as chronic low back pain). If a definitive high quality review has been published and no new trials are available, subsequent reviews are unlikely to be higher quality. | Limiting reviews to the past 5 years was based on the rationale that reviews older than this are often out of date. Although we agree this decision could lead to missing reviews on some interventions (eg, no recent published review), we disagree that it would introduce a bias toward selecting low-quality reviews.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft | 4 | 3. Brief presentation of review findings without any details or quality assessment is potentially misleading. In the pain section in particular, included reviews have limitations that are not acknowledged and some of the best quality reviews seem to be absent. | We agree that brief presentations of intervention effects without quality assessment could be misleading. We've addressed this in several ways. First, we reorganized the report to emphasize sex effects, where we offer more information on review author's comments on the quality of the evidence, and provide discussion of the limits of certain analytic techniques (ie, meta-regression vs IPD meta-analyses). We have also added statements in the Methods and Results sections cautioning readers that the reviews have not been assessed for quality and thus estimates of effect may be wrong.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft | 4 | 4. Page 22, line 41-42: The two reviews were not of “joint injections.” One reviewed facet joint injections and the other reviewed epidural injections. Also, I believe the authors meant to say “reduction in pain” or “improvement in pain relief”, rather than “reduction in pain relief.” Without information about the quality of the reviews, the comparisons, the specific pain indication, or the time frame of the outcomes, the summary statement about improvement may be misleading. (In general, very short term improvement in pain is not considered clinically important in the setting of chronic pain.) | We had defined the term “joint injections” loosely and have now specified these injections as facet and epidural. We have made the edit to “reduction in pain.” We agree that without information about quality, etc., summary statements may be misleading. Therefore, throughout the report, information on general (ie, non-sex-specific) effects of interventions has been moved to Appendices, partially due to several reviewers' correct observation that it had not been collected as rigorously.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft | 4 | 5. Page 22, lines 54-59: The description of this meta-analysis is confusing. It was an indirect (no direct comparisons) meta-analysis of 15 placebo-controlled trials that was sponsored by Eli Lilly with the purpose of comparing duloxetine to other analgesics. It included trials of several typical opioids (“narcotics” “scheduled opioids”), tramadol (“non-scheduled opioids”), duloxetine, paroxetine (“SSRIs”), and etoricoxib (“NSAIDS”). For a variety of reasons (controversial methods, differences in trial designs between drugs), their findings require additional discussion and context. Also, this should not be the only systematic review of medications for LBP. | This information has been moved to an appendix and therefore gets less emphasis. We added the modifier that this was an industry-sponsored study. We did not add an extensive discussion of the strengths and weaknesses of the review, since we did not quality-rate the studies or include this type of discussion for other reviews.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft | 5 | page 7: I had some trouble following the literature flow chart (Figure 1). I wonder if it would be better to break down the figure into 3 smaller figures for depression, diabetes and chronic pain. | We considered this suggestion but decided a single figure was preferable. However, we revised the figure for clarity.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft | 5 | Page 10: did any of the depression studies report on menopausal status? | This is an interesting question but we did not abstract data on menopausal status.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft | 5 | page 25: the second paragraph notes the percentage of studies evaluating sex as a moderator (19%; 9%; 5%). I think this information should be added to the abstract. | We have added this information to the Abstract.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft | 7 | Thank you for this very thorough review. I can only say that I am disappointed in the findings (that very few studies addressed gender differences) not in the quality of the report which was very complete. They only thing I might have considered is including a longer time frame since the last 5 years seemed very short, especially for pain and depression related findings. | We agree it is disappointing that so few studies address sex effects. Limiting the review to the past 5 years was based on the rationale that reviews older than this are often out of date. At this time, we are not able to extend the timeframe for included systematic reviews.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft | 8 | This report is very clearly written and laid out and tackles an important issue within and outside the VA, which is the extent to which sex/gender differences are examined systematically as well as the potential for the larger non-VA literature to help identify opportunities for leveraging national investments in research for use in improving women Veterans' care in the VA health care setting. The review also focuses on top priority conditions of high prevalence and quality of life impact for men and women, offering opportunities to consider differences and potential disparities in a broad way even though this is focused and framed as a Women's Health Evidence Map. Given women's numerical minority in VA, this framing is appropriate. | Thank you for these comments.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft | 8 | The writing and methods are clear and easy to read and follow. The material provided is solid and usefully displayed. Modest issues arise in use of abbreviations throughout the tables and figures, which warrant attention. For example, Figures 4 and 5 on pages 14 and 15 have “psyched” as an abbreviation and while this is likely for psychoeducation, the “psyched” abbreviation has other meanings in our vernacular so some other abbreviation without alternative interpretation would be helpful. | We were able to spell out terms within the figures, and included abbreviation callouts where needed.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft | 8 | The Discussion (and thus Abstract in part) would benefit from clearer presentation of the main takeaway messages. Emphasis appears, perhaps unintentionally, to be on studies often showing greater benefit in women. However, the first takeaway point would seem to take precedence, ie, that a remarkably small fraction of the investment in these trials has been on examining sex/gender differences. The policy implications, however, of readers focusing on the positive findings in that small fraction that examined these issues are potentially very significant and may suffer from publication bias and other issues. In other words, the efforts to require inclusion of women in trial enrollment, analysis and reporting has been underway for decades, with substantial evidence that women's response to pharmaceutical agents, for example, can be meaningfully clinically different than men's. So your primary takeaway message appears to be that this emphasis has failed despite regulatory requirements. Very little time is spent on this failure in the Discussion so the findings lack contextualization. Instead, much more time is spent on the summary of sex effects in the very small fraction of studies that bothered to report on sex/gender differences, and given publication biases toward positive results, we lack adequate knowledge of what might have been found in the large majority that failed to examine these issues. The findings that were gleaned from the review are nonetheless of value, but they are not the whole story --the concern is that they will become the whole story for those looking to avoid the methodological investment of time and resources needed to more definitively characterize intervention effects by subgroup. | We've revised the discussion to address the issues you raise. These changes include moving the summary of sex effects to the results section, moving the table of gaps in evidence to an earlier section of the discussion, and giving more emphasis in the text to the general paucity of studies evaluating sex-specific effects.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft | 8 | Page 27: Very little information is included with respect to what VA has done to increase inclusion of women Veterans in VA research through the Women's Health Research Network, which includes consortium development (ie, training of VA investigators on issues around women Veterans' health and health care; training in oversampling techniques and subgroup analysis approaches) and development of a national practice based research network that facilitates inclusion of women by developing local VA facility capacity to identify, recruit and retain women in VA research. This network is probably worth mentioning/citing, as it is also now responsible for increasing inclusion on women in the VA Cooperative Studies Program. Suggest you consider the following references to support building up this particular and brief paragraph: Frayne SM, Carney DV, Bastian L, Bean-Mayberry B, Sadler AN, Klap R, Phibbs CS, Kimerling R, Vogt D, Yee E, Lin J, Yano EM. The VA women's health practice-based research network: Amplifying women veterans' voices in VA research. J Gen Intern Med. 2013;28(Suppl 2):S504-S509. Bielawski MP, Goldstein K, Mattocks KM, Bean-Mayberry B, Yano EM, Bastian LA. Improving care of chronic conditions for women veterans: What we have learned from comparative effectiveness research. J Comparative Effectiveness, 2014 Mar;3(2):155-166. Yano EM. A partnered research initiative to accelerate implementation of comprehensive care for women Veterans: The VA Women's Health CREATE. Med Care. 2015 Apr;53(4 Suppl 1):S10-14. | Thank you for your comment and suggestions. We have expanded our discussion of VA initiatives to encourage research on women's health topics and improve inclusion of women Veterans in VA research.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft | 8 | I think this report is going to have substantial impacts within and outside the VA both for advancing the tenets of equitable benefits of our research investment by gender and for informing ongoing opportunities for reducing gender disparities and also for targeting scarce resources more efficiently when differences do not indeed exist. | Thank you for your comment and suggestions. We have expanded our discussion of VA initiatives to encourage research on women's health topics and improve inclusion of women Veterans in VA research.