# ELIGIBILITY CRITERIA FOR SYSTEMATIC REVIEWS

PICOTS Element | Inclusion Criteria | Exclusion Criteria
Populations | Depressive disorders: Adults with major depressive disorder, persistent depressive disorder (dysthymia), or subsyndromal depression/minor depression/depression-NOS; also included are reviews broadly addressing effects of treatment in patients with co-occurring chronic medial illness Diabetes: Adults with type 2 diabetes mellitus^a^ Chronic pain: Adults with musculoskeletal causes of chronic low back pain, fibromyalgia, or chronic knee pain due to osteoarthritis | Depressive disorders: Reviews focused on bipolar disorder, grief, premenstrual dysphoric disorder, psychotic depression, depression subtypes (eg, atypical depression; melancholic depression); also excluded are reviews focused on subsets of depressed patients who have a specific comorbid medical condition (eg, diabetes, heart disease) or psychiatric illness (eg, alcohol misuse) Diabetes: None Chronic pain: Reviews focused only on acute back or knee pain, other pain syndromes (eg, patellofemoral)
Interventions | Depressive disorders^b^:; - Antidepressants (SSRI, SNRI, TCA); - Therapy: CBT, CT, IPT, MBCT, PST, ST, psychodynamic, reminiscence therapy delivered in person, in groups, or by internet; - Supervised exercise; - Guided self-help based on principles of CBT; - QI strategies: collaborative care, co-located care, women-only clinic; Diabetes:; - Oral hypoglycemics: metformin, DPP-4 inhibitors (eg, saxagliptin), sulfonylureas (eg, glipizide, glyburide), GLP-1 inhibitors (eg, exanatide, liraglutide), thiazolidenediones (eg pioglitazone); - Insulin; - Exercise programs: aerobic or strengthening performed in organized groups or with support from behaviorist^c^; - Behavioral: psychoeducation, weight control program^d^; - Bariatric surgery; - QI strategies: multidisciplinary care (eg, co-located behaviorist, registered dietician, or diabetic educator), shared medical appointments, chronic disease management (eg, telephone and internet-based interventions), stepped-care models, nurse-managed clinics, women-only clinic, smartphone applications; Chronic pain:; - Antidepressants: SNRIs (duloxetine, venlafaxine, milnacipran), TCA, SSRI; - Calcium channel 2 delta ligands^e^: pregabalin, gabapentin; - Muscle relaxants^e^; - Topical treatments: NSAIDs, capsaicin, lidocaine patch; - Joint injection: steroid (if back, must be lumbar region)^f^, hyaluronic acid^g^; - Behavioral treatments focused on pain management: psychoeducation, CBT, mindfulness-based and acceptance-based therapy, relaxation therapy, biofeedback in groups or by internet; - Exercise: aerobic, strengthening, or stretching performed with supervision (eg, physical therapist, pool therapy), as part of a class (eg, yoga class, tai chi), or as medically directed self-care; - Integrative and complementary medicine^e^: acupuncture; spinal manipulation (chiropractic care); - QI strategies: multidisciplinary care (eg, multidisciplinary pain clinic), co-located care (eg, behaviorist in primary care), women-only clinic; telephone-based care; - Self-management strategies used to decrease pain symptoms | Depressive disorders:; - Alternative: dietary supplements (eg, fish oil; vitamin D), yoga, acupuncture, St. John's wort, SAM-e; - Medications: atypical antipsychotics, ketamine, adjunctive medications used for augmentation (eg, psychostimulants, thyroid hormone, lithium) that have not been specified as eligible medications; reviews of single medications, rather than a drug class, unless review is an individual patient data meta-analysis; - Somatic: electroconvulsive therapy, light therapy, transcranial magnetic stimulation, vagal nerve stimulation, deep brain stimulation; - Psychotherapies: dialectical behavioral therapy, music therapy, traditional long-term psychodynamic therapy, pet therapy; - Treatment sequencing (eg, switching antidepressants); - Interventions to prevent depressive disorder (eg, interferon therapy for hepatitis C); Diabetes:; - Interventions to prevent diabetes; - Alternative: dietary supplements, acupuncture, meditation-based interventions (eg, transcendental meditation); - Medications: any medication or class of medication not listed in the included section, insulin pump regimens, types or intensity of insulin regimens, colesevalam, alpha-glucosidase inhibitors, bromocriptine, miglitol; reviews of single medications unless the medication is insulin, metformin, repaglinide, nateglinide, pioglitazone, rosiglitazone, or pramlintide, or review is an individual patient data meta-analysis; - Somatic: type or intensity of glucose monitoring; - Surgical interventions other than bariatric surgery; - QI: endocrinology clinics, QI interventions with clinician as intervention target (eg, decision support via computer reminders); Chronic pain:; - Complementary and integrative medicine: massage, dietary supplements; - Medications: acetaminophen, oral NSAIDs, antiepileptics (except for gabapentin, pregabalin); antispasmodics; antipsychotics, clozapine, benzodiazepine and opioids; reviews of single medications except: amitriptyline, pregabalin, gabapentin, duloxetine, milnacipran, capsaicin, lidocaine, or review is an individual patient data meta-analysis; - Marijuana/cannabinoids; - Injections/physical: nerve blocks, therapeutic ultrasound, traction, back braces, knee braces, TENS unit, trigger point injections; - Surgical interventions (eg, spinal fusion; total hip or total knee arthroplasty, spinal cord stimulator); - Therapies: dialectical behavioral therapy, music therapy, traditional long-term psychodynamic therapy, pet therapy; - Treatment sequencing (eg, acetaminophen then NSAID); - Interventions to prevent chronic pain
Comparators | All conditions: Any active or inactive comparators | None
Outcomes | All conditions: Patient health outcomes and adverse effects; - Depressive disorders: Depressive symptoms, functional status; - Diabetes: Glycemic control, weight, mortality, microvascular and macrovascular events^h^, adverse effects^i^; - Chronic pain: Pain severity, functional status | Depressive disorders: Provider outcomes, acceptance of intervention, prevalence of intervention, cost of intervention without reporting patient health outcomes Diabetes: Provider outcomes, adherence to and/or acceptance of intervention, blood pressure, lipids, prevalence of intervention, cost of intervention Chronic pain: Provider outcomes, adherence to and/or acceptance of intervention, prevalence of intervention; cost of intervention without reporting patient health outcomes
Timing | Any duration of follow-up | None
Settings | Depressive disorders: Any setting Diabetes: Outpatient settings Chronic pain: Outpatient settings | Depressive disorders: None Diabetes: In-hospital setting, or focused on effects in low-income countries Chronic pain: Focused on work-based programs
Design | All conditions: Systematic reviews or individual patient level meta-analyses; must have search strategy, eligibility criteria, and analysis/synthesis plan; - Depressive disorders: May include RCTs (antidepressants, therapy, exercise), or quasi-experimental studies (QI interventions), or observational studies (if focused on adverse effects); - Diabetes: May include RCTs (medications, behavioral interventions), or quasi-experimental studies (QI interventions), or observational studies (if focused on adverse effects); - Chronic pain: May include RCTs (medications, behavioral, exercise), or quasi-experimental studies (QI strategies), or observational studies (if focused on adverse effects) | Nonsystematic reviews
Publications | English-language only Published October 2009 to present | Non-English publications Publications before October 2009

a Mixed diabetes populations were included if patients with type 2 diabetes were analyzed separately.

b Interventions may be for acute-phase treatment, treatment-resistant depression, or maintenance.

c Includes tai chi, Pilates, yoga, and related forms of exercise.

d Includes supervised programs that use changes in physical activity, diet, or a combination of these approaches to achieve weight change or improved glycemic control.

e For chronic low back pain and fibromyalgia only.

f For chronic low back pain and chronic knee pain only.

g For chronic knee pain only.

h Includes stroke, cardiac event (eg, myocardial infarction), nephropathy, neuropathy (including diabetic foot ulcer), and changes in cognition.

I Includes cancer, osteoporosis, hypoglycemia, changes in cognition, lactic acidosis, adverse gastrointestinal effects, and cardiovascular and serious adverse events.

Abbreviations: CBT=cognitive behavioral therapy; CT=cognitive therapy; DPP-4=dipeptidyl peptidase 4; GLP-1=glucagon-like peptide-1; IPT=interpersonal therapy; MBCT=mindfulness-based cognitive therapy; NOS=not otherwise specified; NSAID=nonsteroidal anti-inflammatory drug; PICOTS=population, intervention, comparator, outcome, timing, setting; PST=problem-solving therapy; QI=quality improvement; RCT=randomized controlled trial; SAM-e=S-adenosylmethionine; SNRI=serotonin-norepinephrine reuptake inhibitor; SSRI=selective serotonin reuptake inhibitor; ST psychodynamic=short-term psychodynamic; TCA=tricyclic antidepressant; TENS= transcutaneous electrical nerve stimulation