# SEARCH STRATEGIES

## CONDITION: MAJOR DEPRESSIVE DISORDER

PubMed: Searched October 31, 2014

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Depressive Disorder”[Mesh:NoExp] OR “Depressive Disorder, Major”[MeSH] OR “major depressive disorder”[tiab] OR “major depressive disorders”[tiab] OR “major depression”[tiab] OR “Involutional Psychoses”[tiab] OR “Involutional Psychosis”[tiab] OR “Involutional Depression”[tiab] OR “Involutional Melancholia”[tiab] OR “Dysthymic Disorder”[Mesh] OR “Dysthymic Disorder”[tiab] OR “Dysthymic Disorders”[tiab] OR “dysthymia”[tiab] | 87024 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Psychotherapy”[Mesh] OR “Behavior Therapy”[Mesh] OR acceptance therap*[tiab] OR commitment therap*[tiab] OR cognitive therap*[tiab] OR behavioral therap*[tiab] OR behavior therap*[tiab] OR behaviour therap*[tiab] OR behavioural therap*[tiab]OR interpersonal therap*[tiab] OR acceptance therap*[tiab] OR commitment therap*[tiab] OR mindfulness therap*[tiab] OR problem-solving therap*[tiab] OR problem solving therap*[tiab] OR psychodynamic therap*[tiab] OR psychotherap*[tiab] | 172225 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “antidepressive agents”[Pharmacological Action] OR “antidepressive agents”[MeSH Terms] OR “antidepressive”[tiab] OR antidepressant*[tiab] | 141775 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Delivery of Health Care, Integrated”[Mesh] OR “Patient Care Team”[Mesh] OR “Patient Care Planning”[Mesh] OR “Disease Management”[Mesh] OR “Comprehensive Health Care” [Mesh:noexp] OR “Patient Care Management”[Mesh:noexp] OR “coordinated care”[tiab] OR coordinated program*[tiab] OR “team care”[tiab] OR “team treatment”[tiab] OR “team assessment”[tiab] OR “team consultation”[tiab] OR (collaborat*[ti] AND care [ti]) OR “shared care”[tiab] OR (collaborat*[ti] AND manage*[ti]) OR “Quality Improvement”[Mesh] | 154585 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed) | (“Exercise”[Mesh:NoExp] OR “Exercise”[Majr] OR “Circuit-Based Exercise”[Mesh] OR “Muscle Stretching Exercises”[Mesh] OR “Physical Conditioning, Human”[Mesh] OR “Resistance Training”[Mesh] OR “Resistance Training”[tiab] OR “Exercise”[tiab] OR “Exercises”[tiab] OR “physical activity”[tiab] OR “aerobic activity”[tiab] OR “Exercise Movement Techniques”[Mesh] OR “Sports”[Mesh] OR “yoga”[tiab] OR “Exercise Therapy”[Mesh]
#5 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #1 AND (#2 OR #3 OR #4 OR #5) | 32393 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #5 AND (systematic[sb] OR “Systematic Review”[tiab] OR meta-analysis[tiab] OR “meta analysis”[tiab]) | 1792 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #6 NOT ((“Adolescent”[Mesh] OR “Child”[Mesh] OR “Adolescent”[Mesh]) NOT “Adult”[Mesh]) | 1677 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #7 NOT (“Animals”[Mesh] NOT “Humans”[Mesh]) | 1677 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #7 NOT (“Animals”[Mesh] NOT “Humans”[Mesh]) Filters: published in the last 5 years | 631 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #7 NOT (“Animals”[Mesh] NOT “Humans”[Mesh]) Sort by: Author Filters: published in the last 5 years; English | 581 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)

Cochrane Library: Searched October 31, 2014

ID | Search | Results
#1 | major depressive disorder:ti,ab,kw (Word variations have been searched) | 2783
#2 | major depression:ti,ab,kw (Word variations have been searched) | 3691
#3 | major depression disorder:ti,ab,kw (Word variations have been searched) | 24
#4 | dysthymic disorder:ti,ab,kw (Word variations have been searched) | 241
#5 | dysthymia:ti,ab,kw (Word variations have been searched) | 379
#6 | involutional depression:ti,ab,kw (Word variations have been searched) | 12
#7 | involutional melancholia:ti,ab,kw (Word variations have been searched) | 0
#8 | involutional psychosis:ti,ab,kw (Word variations have been searched) | 0
#9 | involutional psychoses:ti,ab,kw (Word variations have been searched) | 0
#10 | (or #1-#9) | 6077
#11 | #10 Publication Year from 2009 to 2014, in Cochrane Reviews (Reviews only) and Other Reviews | 117

## CONDITION: TYPE 2 DIABETES

PubMed: Searched February 6, 2015

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Diabetes Mellitus, Type 2”[Mesh] OR “Type 2 Diabetes Mellitus”[tiab] OR “Type II Diabetes Mellitus”[tiab] OR “Adult-Onset Diabetes Mellitus”[tiab] OR “Adult Onset Diabetes Mellitus”[tiab] OR “Maturity-Onset Diabetes Mellitus”[tiab] OR “Maturity Onset Diabetes Mellitus”[tiab] OR “Non-Insulin-Dependent Diabetes Mellitus”[tiab] OR “Non-Insulin Dependent Diabetes Mellitus”[tiab] OR “Noninsulin Dependent Diabetes Mellitus”[tiab] OR “Ketosis-Resistant Diabetes Mellitus”[tiab] OR “Ketosis Resistant Diabetes Mellitus”[tiab] OR “Stable Diabetes Mellitus”[tiab] | 97698 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Hypoglycemic Agents”[Mesh] OR “Hypoglycemic Agents”[Pharmacological Action] OR “Metformin”[Mesh] OR “Metformin”[tiab] OR “Glyburide”[Mesh] OR “Glyburide”[tiab] OR “Glipizide”[Mesh] OR “Glipizide”[tiab] OR “glibenclamide receptor”[Supplementary Concept] OR “glibenclamide”[tiab] OR “Gliclazide”[Mesh] OR “Gliclazide”[tiab] OR “glimepiride”[Supplementary Concept] OR “glimepiride”[tiab] OR “repaglinide”[Supplementary Concept] OR “repaglinide”[tiab] OR “nateglinide”[Supplementary Concept] OR “nateglinide”[tiab] OR “pioglitazone”[Supplementary Concept] OR “pioglitazone”[tiab] OR “rosiglitazone”[Supplementary Concept] OR “rosiglitazone”[tiab] OR “Acarbose”[Mesh] OR “Acarbose”[tiab] OR “miglitol” [Supplementary Concept] OR “miglitol”[tiab] OR “sitagliptin”[Supplementary Concept] OR “sitagliptin”[tiab] OR “vildagliptin”[Supplementary Concept] OR “vildagliptin”[tiab] OR “saxagliptin”[Supplementary Concept] OR “saxagliptin”[tiab] OR “Linagliptin”[Supplementary Concept] OR “Linagliptin”[tiab] OR “alogliptin”[Supplementary Concept] OR “alogliptin”[tiab] OR “colesevelam”[Supplementary Concept] OR “colesevelam”[tiab] OR “Bromocriptine”[Mesh] OR “Bromocriptine”[tiab] OR “canagliflozin”[Supplementary Concept] OR “canagliflozin”[tiab] OR “2-(3-(4-ethoxybenzyl)-4-chlorophenyl)-6-hydroxymethyltetrahydro-2H-pyran-3,4,5-triol”[Supplementary Concept] OR “dapagliflozin”[tiab] OR “empagliflozin”[Supplementary Concept] OR “empagliflozin”[tiab] OR “exenatide”[Supplementary Concept] OR “exenatide”[tiab] OR “liraglutide”[Supplementary Concept] OR “liraglutide”[tiab] OR “albiglutide”[Supplementary Concept] OR “albiglutide”[tiab] OR “ZP10A peptide”[Supplementary Concept] OR “Lixisenatide”[tiab] OR “dulaglutide”[Supplementary Concept] OR “dulaglutide”[tiab] OR “pramlintide”[Supplementary Concept] OR “pramlintide”[tiab] | 220517 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #1 AND #2 | 31000 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Insulins”[Mesh] OR “Lispro”[tiab] OR “Aspart”[tiab] OR “insulin glulisine”[Supplementary Concept] OR “glulisine”[tiab] OR “isophane insulin, human”[Supplementary Concept] OR “glargine”[Supplementary Concept] OR “glargine”[tiab] OR “insulin detemir”[Supplementary Concept] OR “detemir”[tiab] OR “insulin degludec”[Supplementary Concept] OR “degludec”[tiab] | 162510 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #1 AND #4 | 18805 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Exercise”[Mesh] OR “Exercise”[tiab] OR “Exercise Therapy”[Mesh] OR “physical activity”[tiab] | 296513 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #1 AND #6 | 6871 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Weight Reduction Programs”[Mesh] OR “Weight Reduction Program”[tiab] OR “Weight control Program”[tiab] OR “Nutrition Therapy”[Mesh] OR “weight management”[tiab] | 83630 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #1 AND #8 | 2694 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Bariatric Surgery”[Mesh] OR “Bariatric Surgery”[tiab] | 17552 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #1 AND #10 | 1329 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Patient Care Management”[Mesh] OR “multidisciplinary care”[tiab] OR “shared medical appointments”[tiab] OR “chronic disease management”[tiab] OR “stepped-care models”[tiab] OR “stepped-care model”[tiab] OR “stepped care models”[tiab] OR “stepped care model”[tiab] OR (nurse managed clinic[tiab] OR nurse managed clinics[tiab]) OR (nurse managed clinic[tiab] OR nurse managed clinics[tiab]) OR “Cell Phones”[Mesh] OR “smartphone applications”[tiab] OR “Quality Improvement”[Mesh] | 554128 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #1 AND #12 | 3965 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #3 OR #5 OR #7 OR #9 OR #11 OR #13 | 41293 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #14 NOT ((“Adolescent”[Mesh] OR “Child”[Mesh] OR “Infant”[Mesh]) NOT “Adult”[Mesh]) | 40423 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #15 NOT (“Animals”[Mesh] NOT “Humans”[Mesh]) | 37107 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #16 AND (systematic[sb] OR “Systematic Review”[tiab] OR “Umbrella Review”[tiab] OR meta-analysis[tiab] OR “meta analysis”[tiab]) AND “English”[lang] | 1442 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)

## CONDITION: CHRONIC PAIN

PubMed: Searched February 27, 2015

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “chronic pain”[MeSH Terms] OR “chronic pain”[tiab] OR “chronic pains”[tiab] OR “Fibromyalgia”[Mesh] OR “Fibromyalgia”[tiab] OR “Fibromyalgias”[tiab] OR “Muscular Rheumatism”[tiab] OR “Fibrositis”[tiab] OR “Pain Syndrome”[tiab] OR “chronic low back pain”[tiab] OR “chronic knee pain”[tiab] OR “knee osteoarthritis”[MeSH Terms] OR “knee osteoarthritis”[tiab] | 41472 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #1 AND (systematic[sb] OR “Systematic Review”[tiab] OR “Umbrella Review”[tiab] OR meta-analysis[tiab] OR “meta analysis”[tiab]) AND “English”[lang] | 2031 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #2 NOT (“Animals”[Mesh] NOT “Humans”[Mesh]) | 2025 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #3 NOT ((“Adolescent”[Mesh] OR “Child”[Mesh] OR “Infant”[Mesh]) NOT “Adult”[Mesh]) | 1985 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((“2009/10/01”[Date - Publication] : “3000”[Date - Publication])) AND #4 | 1145 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #5 AND (“Behavior Therapy”[Mesh] OR “psychoeducation”[tiab] OR “CBT”[tiab] OR “biofeedback”[tiab] OR ((“therapy”[tiab]) AND (“mindfulness”[tiab] OR “cognitive”[tiab] OR “behavior”[tiab] OR “behavioral”[tiab] OR “relaxation”[tiab] OR “acceptance”[tiab]))) | 92 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #5 AND (“Exercise”[Mesh:NoExp] OR “Exercise”[Majr] OR “Circuit-Based Exercise”[Mesh] OR “Muscle Stretching Exercises”[Mesh] OR “Physical Conditioning, Human”[Mesh] OR “Resistance Training”[Mesh] OR “Resistance Training”[tiab] OR “Running”[Mesh] OR “Running”[tiab] OR “Jogging”[Mesh] OR “Jogging”[tiab] OR “Swimming”[Mesh] OR “Swimming”[tiab] OR “Walking”[Mesh] OR “Walking”[tiab] OR “Exercise”[tiab] OR “Exercises”[tiab] OR “physical activity”[tiab] OR “aerobic activity”[tiab] OR “Exercise Movement Techniques”[Mesh] OR “Sports”[Mesh] OR “yoga”[tiab] OR “Physical Therapy Modalities”[Mesh:NoExp] OR “Physical Therapy”[tiab] OR “Exercise Therapy”[Mesh] OR “Hydrotherapy”[Mesh] OR “Hydrotherapy”[tiab]) | 196 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #5 AND (“Muscle Relaxants, Central”[Mesh] OR “Baclofen”[Mesh] OR “Baclofen”[tiab] OR “Carisoprodol”[Mesh] OR “Carisoprodol”[tiab] OR “cyclobenzaprine” [Supplementary Concept] OR “cyclobenzaprine”[tiab] OR “Methocarbamol”[Mesh] OR “Methocarbamol”[tiab] OR “tizanidine”[Supplementary Concept] OR “tizanidine”[tiab]) | 2 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #5 AND (“Anti-Inflammatory Agents, Non-Steroidal” [Pharmacological Action] OR “Anti-Inflammatory Agents, Non-Steroidal”[Mesh] OR “NSAIDs”[tiab] OR “Nonsteroidal Anti Inflammatory Agents”[tiab] OR “Nonsteroidal Anti Inflammatory Agent”[tiab]) | 41 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #5 AND (“Capsaicin”[Mesh] OR “Capsaicin”[tiab]) | 10 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #5 AND ((“Lidocaine”[MeSH Terms] OR “lidocaine”[tiab]) AND (“transdermal patch”[MeSH Terms] OR “transdermal”[tiab] OR “patch”[tiab])) | 1 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #5 AND (“Antidepressive Agents”[Mesh] OR “Antidepressive Agents” [Pharmacological Action] OR “Duloxetine”[tiab] OR “Venlafaxine”[tiab]) | 60 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #5 AND (“pregabalin” [Supplementary Concept] OR “pregabalin” [tiab]) | 38 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #5 AND (“gabapentin” [Supplementary Concept] OR “gabapentin” [tiab]) | 23 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #5 AND (“Hyaluronic Acid”[Mesh] OR “Hyaluronic Acid”[tiab]) | 4 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #5 AND (“Steroids”[Mesh] OR “steroid”[tiab] OR “steroids”[tiab]) | 28 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #5 AND (“Acupuncture Therapy”[Mesh] OR “Acupuncture”[Mesh] OR “Acupuncture”[tiab] OR “Chiropractic”[Mesh] OR “Manipulation, Chiropractic”[Mesh] OR “Chiropractic”[tiab] OR “Chiropractor”[tiab]) | 58 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #5 AND (“Patient Care Management”[Mesh] OR “multidisciplinary care”[tiab] OR “colocated care”[tiab] OR “shared medical appointments”[tiab] OR “pain clinic”[tiab] OR “Telephone”[MAJR] OR “Cell Phones”[Mesh] OR “smartphone applications”[tiab] OR “telephone-based care”[tiab] OR “telephone care”[tiab] OR “Quality Improvement”[Mesh] OR “Continuity of Patient Care”[Mesh] OR “Patient-Centered Care”[Mesh] OR “chronic disease management”[tiab]) | 196 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17 OR #18 | 538 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)

Cochrane Library: Searched February 27, 2015

ID | Search | Results
#1 | “chronic pain”:ti,ab,kw (Word variations have been searched) | 2689
#2 | “fibromyalgia”:ti,ab,kw (Word variations have been searched) | 1249
#3 | #1 or #2 Publication Year from 2009 to 2015, in Cochrane Reviews (Reviews and Protocols) | 88