# CONDITION PRIORITIZATION INSTRUCTIONS

Please prioritize the list of health conditions by assigning 0 to 3 stars to items listed below. When prioritizing, consider the following: (1) prevalence of the condition in Veterans, (2) the burden of the illness, (3) priorities for gender-specific care for women Veterans (not Active Duty), and (4) conditions with known disparities between women Veterans and non-Veterans. Items are categorized by conditions affecting men and women compared with gender-specific conditions.

You are given a total of 11 stars to allocate to any of the 34 items listed in the 2 categories. You may use up to 3 stars per item. To add stars to a selection, position your mouse over the dots in the right hand column. More stars equal higher priority.

- Alzheimer's disease
- Anxiety (ie, GAD, panic disorder)
- Osteoporosis
- Coronary artery disease (ie, chronic angina)
- Coronary artery disease (ie, acute coronary syndrome/myocardial infarction)
- Chronic obstructive pulmonary disease
- Cerebrovascular disease (ie, ischemic stroke)
- Depression (ie, MDD & dysthymia)
- Diabetes mellitus-type2
- Eating disorders
- Connective tissue disease (ie, fibromyalgia)
- Headache (ie, migraine)
- Hepatitis-C
- HIV
- Hyperlipidemia
- Hypertension
- Irritable bowel syndrome
- Incontinence
- Insomnia
- Joint disorders (ie, osteoarthritis: hip and knee)
- Joint disorders (ie, rheumatoid arthritis)
- Obesity/overweight
- Chronic pain
- Posttraumatic stress disorder
- Spine disorders (ie, chronic low back pain)
- Substance use disorder
- Traumatic brain injury
- Thyroid disorders
- Tobacco use disorder

SEPARATOR BETWEEN SEX-SPECIFIC ITEMS
- Contraceptive care
- Infertility
- Menstrual disorders (ie, abnormal uterine bleeding)
- Menopausal disorders
- Depressive disorders (ie, postpartum depression)
- Depressive disorders (ie, premenstrual dysphoric disorder)
- Prenatal care