# RESULTS

## LITERATURE SEARCH

The flow of articles through the literature search and screening process is illustrated in Figures 2 and 3. Our search for RCTs (Figure 2) identified 594 unique citations from a combined search of MEDLINE via PubMed (n = 338), Embase (n = 178), and the Cochrane Database of Systematic Reviews (n = 78). Manual searching of included study bibliographies and review articles identified an additional 17 citations for a total of 611 unique citations. After applying inclusion and exclusion criteria at the title-and-abstract level, 80 full-text articles were retrieved and screened. Of these, 56 were excluded at the full-text screening stage, leaving 24 articles (representing 8 unique studies) for data abstraction.

Figure 2 Literature flow diagram for RCTs

Abbreviations: AF = atrial fibrillation; VTE = venous thromboembolism; KQ = key question

Figure 3 Literature flow diagram for observational studies and systematic reviews

Abbreviations: KQ = key question

Our search of the observational literature including systematic reviews via PubMed (Figure 3) identified 369 unique citations. An additional 8 citations were identified from personal communications of experts and bibliographies of included studies for a total of 377 unique citations. After applying inclusion and exclusion criteria specifically for observational designs at the title-and-abstract level, 28 full-text articles were retrieved and screened. Of these, 10 contained new data and were abstracted either as unique studies (n = 7)70,77–82 or as additional analyses from earlier trials (n = 3).72,83,84

Appendix C provides a complete listing of published articles excluded at the full-text screening stage, with reasons for exclusion.

Our search of the FDA website, Drugs@FDA, identified two MedWatch reports of adverse events with dabigatran (QuarterWatch 10/6/2011 and 1/12/2012) and one FDA Drug Safety Communication on dabigatran. We also examined the FDA Advisory Committee Briefing Reports, FDA Summary Reviews, and the medical and statistical reviews on dabigatran and rivaroxaban. These reports are detailed under KQ 4.

Finally, we searched www.clinicaltrials.gov, which revealed nine unpublished studies that met our eligibility criteria (Appendix F). Of these, four are ongoing trials and two have completed data collection within the last 6 months. The other three trials (NCT00645853, NCT00448214, NCT00329238) were scheduled for completion more than a year ago (between 2008 and 2010). Of these, two examined chronic AF and one examined venous thromboembolism. When the sponsors were contacted, we received the following information: (1) A 5-year RCT of AZD0837 in patients with chronic AF (NCT00645853) was terminated early due to “a limitation in the long-term stability of the AZD0837 drug product”; (2) development of darexaban maleate (YM150, examined in NCT00448214) was stopped for financial reasons prior to Phase III trials; and (3) an abstract reporting longer term outcomes (NCT00329238) from the dabigatran RECOVER study85 was presented at the 2011 International Symposium on Hemostasis and Thrombosis in Kyoto, Japan.

## STUDY CHARACTERISTICS

### Randomized Controlled Trials

We identified 8 randomized studies involving 66,449 subjects.85–92 Five studies evaluated newer oral anticoagulants for chronic AF, and three studies examined the treatment of venous thromboembolism; no study evaluated newer oral anticoagulants for patients with mechanical heart valves. All studies compared newer oral anticoagulants to adjusted-dose warfarin; there were no direct comparisons between newer oral anticoagulants.

Seven studies were conducted in multisite trials that included U.S. sites and one study was conducted outside the United States. None of the studies were conducted in VA settings. All studies were judged good quality (Appendix G), although there were design features that may have affected the findings: (1) patients not blinded to treatment assignment (seven of eight studies), (2) uncertainty whether outcomes assessors were blinded to treatment status (one study),87 and (3) uncertainty whether all outcomes were reported (one study).89

For the five studies conducted in patients with chronic AF, key exclusion criteria were marked renal impairment (5 studies), aspirin use of more than 100 mg (4 studies) or more than 165 mg daily (1 study), uncontrolled hypertension (4 studies), prior stroke (4 studies), significant anemia (4 studies), and platelet count lower than 90,000 to 100,000 (4 studies). Exclusion criteria were somewhat less stringent for the VTE studies. For the three VTE studies, key exclusion criteria were marked renal impairment (3 studies), uncontrolled hypertension (1 study), prior stroke (1 study), and low platelet count (1 study). Table 3 presents an overview of study characteristics of the included studies, and Table 4 provides further details.

Table 3 Overview of study characteristics for included RCTs

Study Characteristic | Chronic Atrial Fibrillation Number of studies (patients) | Venous Thromboembolism Number of studies (patients)^a^
Studies | 5 (57,908) | 3 (8541)
Factor Xa inhibitors
Apixaban | 1 (18,201) | –
Rivaroxaban | 1 (14,262) | 1 (3449)
Direct thrombin inhibitors
Dabigatran | 1 (18,113) | 1 (2564)
Ximelagatran | 2 (7332) | 1 (2528)
Study country
Multiple countries (with U.S.) | 4 | 3
Multiple countries (without U.S.) | 1 | –
Study duration
6 months | – | 2 (5092)
6–12 months | – | 1 (3449)
>12 months–2 years | 5 (57,908) | –
Mean age
Age 50–59 | – | 3 (8541)
Age 60–69 | – | –
Age 70–75 | 5 (57,908) | –
Funding source
Industry | 5 | 3
Government | – | –
Outcomes reported
Mortality | 5 | 3
Thromboembolic-related mortality | 4 | 3
Thromboembolic events | 5 | 3
Major bleeding | 5 | 3
Adverse effects | 5 | 3
Health-related quality of life | – | –
Patient treatment experience | – | –
Study quality
Good | 5 | 3

a Represents number of patients randomized but does not include the third treatment arm (110 mg dabigatran) from Connolly et al., 2009.

Table 4 Details of study characteristics

Study | RCT n | Quality^a^ | Intervention vs. Comparator | Outcome Measures^b^ | Adverse Effects
Chronic nonvalvular AF: KQ 1 and KQ 4
Albers et al., 2005^88^ (SPORTIF V study) | n = 3922 | Good | Ximelagatran (DTI) 36 mg vs. warfarin | All-cause mortality Death–thromboembolic event Stroke–ischemic Stroke–hemorrhage Peripheral embolism | Serious adverse events
Connolly et al., 2009^87^ (RELY study) | n = 18113 | Good | Dabigatran (DTI) 150 mg vs. warfarin | All-cause mortality Death–thromboembolic event Stroke–hemorrhage Combined stroke Peripheral embolism | Major bleeding Fatal bleeding Myocardial infarction Intracranial bleeding
Granger et al., 2011^92^ (ARISTOTLE study) | n = 18201 | Good | Apixaban (FXa) 5 mg vs. warfarin | All-cause mortality Death–thromboembolic event Stroke–ischemic Stroke–hemorrhage Combined stroke Peripheral embolism | Adverse effects drug discontinuation Major bleeding Major bleeding requiring transfusion Myocardial infarction Intracranial bleeding
Olsson et al., 2003^90^ (SPORTIF III study) | n = 3410 | Good | Ximelagatran (DTI) 36 mg vs. warfarin | All-cause mortality Death–thromboembolic event Stroke–ischemic Stroke–hemorrhage Peripheral embolism | NR
Patel et al., 2011^91^ (ROCKET-AF study) | n = 14264 | Good | Rivaroxaban (FXa) 20 mg vs. warfarin | All-cause mortality Stroke–ischemic Stroke–hemorrhage Combined stroke | Major bleeding Fatal bleeding Major bleeding requiring transfusion Myocardial infarction Intracranial bleeding
Venous thromboembolism: KQ 2 and KQ 4
Bauersachs et al., 2005^86^ (EINSTEIN- DVT study) | n = 3449 | Good | Rivaroxaban (FXa) 20 mg vs. warfarin | All-cause mortality Death–thromboembolic event Recurrent DVT PE Recurrent DVT/PE | Major bleeding
Fiessinger et al., 2005^89^ (THRIVE study) | n = 2528 | Good | Ximelagatran (DTI) 36 mg vs. warfarin | All-cause mortality Recurrent DVT PE Recurrent DVT/PE | Major bleeding
Schulman et al., 2009^85^ (RECOVER study) | n = 2564 | Good | Dabigatran (DTI) 150 mg vs. warfarin | All-cause mortality Death–thromboembolic event Recurrent DVT PE | All adverse effects Serious adverse events Adverse effects drug discontinuation Major bleeding Myocardial infarction

a Study quality assessed using key quality criteria described in Methods Guide for Effectiveness and Comparative Effectiveness Reviews

b Outcomes limited to those with direct relevance to KQs 1, 2, and 4 (i.e., chronic AF, venous thromboembolism, adverse effects).

Abbreviations: DTI= direct thrombin inhibitors; DVT = deep venous thrombosis; FXa = factor Xa inhibitor; PE = pulmonary embolism

## KEY QUESTION 1 For patients with chronic nonvalvular AF, what is the comparative effectiveness of long-term anticoagulation using newer oral anticoagulants versus warfarin on stroke incidence, mortality, health-related quality of life (HRQOL), and patient treatment experience?

We identified five good-quality studies relevant to KQ 1, which involved 57,908 patients. All studies were funded by the pharmaceutical industry. These studies compared apixaban,92 dabigatran,87 rivaroxaban,91 and ximelagatran88,90 to adjusted-dose warfarin. Two studies91,92 modified the drug dose for patients with impaired renal function. In the study by Granger et al.,92 this was due to older age (>80 years), lower weight (<60 kg), or high creatinine (>1.5 mg/dl). In the study by Patel et al.,91 this was due to creatinine clearance less that 30 mL/minute. The mean age of participants in all studies was over 70 years; about 55 percent were men. CHADS2 stroke risk scores averaged approximately 2.1 in the studies evaluating dabigatran and apixaban87,92 and 3.5 in the study evaluating rivaroxaban;91 two studies did not report CHADS2 scores.88,90 Average adherence to the intervention drugs was greater than 90 percent for two studies88,90 and in another study, 79 percent of participants took at least 80 percent of prescribed medication doses87; two studies did not report adherence.91,92 In the control groups, the percentage of time in the INR target range was 55 to 68 percent (median 66%). All studies planned outcomes assessment over 24 months; none reported effects on HRQOL or patient experience. Study characteristics are summarized in Table 5.

Table 5 Summary table for KQ 1—chronic atrial

Study Characteristic | Number of Studies (Patients)^a^
Total number of studies (patients) | 5 studies (57,908)
Factor Xa inhibitors, dose
Apixaban, 5 mg twice daily | 1 (18,201)
Rivaroxaban, 20 mg daily | 1 (14,262)
Direct thrombin inhibitors, dose
Dabigatran, 150 mg twice daily | 1 (18,113)
Ximelagatran, 36 mg twice daily | 2 (7,332)
Mean age
50–60 years | –
60–70 years | –
≥70 years | 5 (57,908)
Sex^b^
Men | 5 (33107)
Women | 5 (18785)
Baseline CHADS2 stroke risk score^c^
≤1 | 3 (10,207)
2 | 3 (12,742)
≥3 | 3 (20,822)
NR | 2
Adjusted-dose warfarin range
Time above range (%) | 1 (12%), 4 NR
Time in range (%) | 5 (median 66%, range: 55–68%)
Time below range (%) | 1 (20%), 4 NR

a Does not include the third treatment arm (110 mg dabigatran) from Connolly et al., 2009.

b Does not match randomized total because some patient characteristics were reported only for those subjects analyzed.

c CHADS2 is a clinical score ranging from 0 to 6 used to predict the annual risk of stroke in individuals with chronic nonvalvular AF.

Abbreviations: NR = not reported

### Meta-Analyses for KQ 1

We used random-effects model meta-analyses to evaluate the effects of newer oral anticoagulants compared with adjusted-dose warfarin on mortality, risk of ischemic and hemorrhagic stroke, major bleeding, fatal bleeding, myocardial infarction, liver dysfunction, and drug discontinuation due to an adverse event (Table 6, Figures 4–9). For our primary analyses, we excluded the studies using ximelagatran since this drug is not available in the U.S. All-cause mortality (summary RR 0.88; 95% CI, 0.82 to 0.95), hemorrhagic stroke (RR 0.46; CI, 0.31 to 0.68), hemorrhagic or ischemic stroke (RR 0.77; CI, 0.67 to 0.88), and fatal bleeding (RR 0.55; CI, 0.41 to 0.76) were lower with the newer oral anticoagulants. Tests for heterogeneity suggest important variability in treatment effects across studies for death due to thromboembolism, hemorrhagic stroke, drug discontinuation due to adverse effects, major bleeding, and myocardial infarction.

Table 6 Effects of newer oral anticoagulants compared with adjusted-dose warfarin for chronic AF

Outcome | Summary Risk Ratios (95% CI) | Test for Heterogeneity | Summary Risk Ratios (95% CI) | Test for Heterogeneity
Outcome | Non-ximelagatran studies (n = 3) | | All studies (n = 5)
All-cause mortality | 0.88 (0.82 to 0.95) | Q = 0.49, I^2^ = 0% p = 0.78 | 0.89 (0.83 to 0.96) | Q = 1.15, I^2^ = 0% p = 0.89
Death–thromboembolic^a^ | 0.77 (0.57 to 1.03) | Q = 2.23, I^2^ = 55% p = 0.14 | 0.91 (0.61 to 1.36) | Q = 7.85, I^2^ = 62% p = 0.05
Stroke–ischemic | 0.89 (0.78 to 1.02) | Q = 1.77, I^2^ = 0% p = 0.41 | 0.90 (0.78 to 1.04) | Q = 5.30, I^2^ = 25% p = 0.26
Stroke–hemorrhagic | 0.45 (0.31 to 0.68) | Q = 4.18, I^2^ = 52% p = 0.12 | 0.47 (0.35 to 0.64) | Q = 4.74, I^2^ = 16% p = 0.31
Combined stroke | 0.77 (0.67 to 0.88) | Q = 2.80, I^2^ = 29% p = 0.25 | NA | NA
Peripheral embolism^a^ | 1.17 (0.64 to 2.14) | Q = 1.38, I^2^ = 28% p = 0.24 | 1.40 (0.78 to 2.51) | Q = 3.84, I^2^ = 22% p = 0.28
Adverse Effect
Discontinued due to adverse effects | 1.26 (0.86 to 1.84) | Q = 56.27, I^2^ = 96% p < 0.001 | 1.41 (1.05 to 1.89) | Q = 76.37, I^2^ = 95% p < 0.001
Major bleeding | 0.88 (0.70 to 1.09) | Q = 15.45, I^2^ = 87% p < 0.001 | 0.84 (0.71 to 1.00) | Q = 16.44, I^2^ = 82% p = 0.001
Fatal bleeding | 0.55 (0.41 to 0.76) | Q = 0.49, I^2^ = 0% p = 0.48 | 0.57 (0.42 to 0.77) | Q = 1.57, I^2^ = 0% p = 0.67
Myocardial infarction | 0.97 (0.72 to 1.30) | Q = 6.37, I^2^ = 69% p = 0.04 | 0.99 (0.75 to 1.31) | Q = 11.52, I^2^ = 65% p = 0.02
Liver dysfunction | 0.97 (0.82 to 1.15) | Q = 1.61, I^2^ = 0% p = 0.45 | 2.18 (0.96 to 4.95) | Q = 99.92, I^2^ = 96% p < 0.001

a No data for Patel 2011.

Abbreviation: NA = not applicable

There were too few studies to conduct quantitative analyses for factors that may be associated with variable treatment effects. However, a qualitative inspection shows differences in the study eligibility criteria that may contribute to differential treatment effects. The study by Patel et al.91 found the greatest effect on mortality and enrolled an older patient population with higher CHADS2 scores than the other studies.9 Older age is a risk factor for both thrombosis and bleeding,22,93 and a higher CHADS2 score is associated with a higher risk of stroke, systemic embolism, and death.94 Variation in effects may also be related to different definitions for outcomes. For example, adverse effects leading to drug discontinuation include liver disease and bleeding. Liver disease was defined in two of three included AF studies as liver enzymes elevated to twice the upper limit of normal,87,92 while one study defined it as three or more times the upper limit of normal.91

We conducted two sensitivity analyses, first by including studies of ximelagatran and second by using the data from the dabigatran 110 mg treatment arm instead of the 150 mg treatment arm in the study by Connolly et al.87 When the two studies examining ximelagatran are included, results are similar except that drug discontinuation due to adverse effects and rates of liver dysfunction are significantly higher than rates with adjusted-dose warfarin. Using data from the dabigatran 110 mg treatment arm, risk ratios did not differ by more than 10 percent except for ischemic stroke (summary RR 1.0; 95% CI, 0.88 to 1.13) and peripheral emboli (RR 1.03; CI, 0.61 to 1.74). Summary risk ratios and tests for variability in treatment effects across studies are summarized in Table 6. There were too few studies to conduct meaningful analyses by drug class or statistical tests for publication bias. However, our search of www.clinicaltrials.gov did not suggest publication bias.

#### Forest Plots for Studies Without Ximelagatran (Atrial Fibrillation)

Figure 4 AF: All-cause mortality without ximelagatran^a^

Figure 5 AF: Ischemic stroke without ximelagatran^a^

Figure 6 AF: Hemorrhagic stroke without ximelagatran^a^ a Studies evaluating ximelagatran are shown but not incorporated into the summary risk ratio in Figures 4, 5, and 6.

#### Forest Plots for Studies With Ximelagatran (Atrial Fibrillation)

Figure 7 AF: All-cause mortality with ximelagatran

Figure 8 AF: Ischemic stroke with ximelagatran

Figure 9 AF: Hemorrhagic stroke with ximelagatran

### Subgroup Analyses From Primary Publications

#### SPORTIF III and V Trials (Ximelagatran Versus Warfarin)

In three industry-sponsored, pooled analyses on the combined sample (n = 7329) of the SPORTIF III and V trials, the following results were reported:

- There was no significant difference in the primary event rate (stroke or systemic embolism) for patients with a history of stroke or transient ischemic attack (TIA) compared with those without a prior history of stroke or TIA. Similarly, there was no difference between these groups in the incidence of cerebral hemorrhage.95
- Ximelagatran was comparable to warfarin for stroke prevention in adults under age 75 and those older than age 75. Risk of bleeding with ximelagatran was lower than warfarin in both the younger and older subgroups.96
- Patients with markers of heart failure compared to patients without markers of heart failure had a higher rate of stroke or systemic embolic events. Ximelagatran was comparable to warfarin for these outcomes in patients with or without markers of heart failure.97

#### RE-LY Trial (Dabigatran Versus Warfarin)

In the RE-LY trial, the following results were reported:

- Diener et al. performed a subgroup analysis for the primary outcome, stroke or systemic embolism, and seven secondary outcomes in patients with and without a history of previous stroke or TIA.98 Treatment effects did not differ significantly by subgroup except for the secondary outcome of vascular death. For this outcome, dabigatran 110 mg was more effective in the group with prior stroke or TIA compared with those without prior stroke or TIA (OR 0.63 versus 0.98, p = 0.038). However, this finding was not replicated in the dabigatran 150 mg treatment arm.
- Because therapeutic INR with warfarin anticoagulation control is key for stroke prevention, Walletin et al. performed a subgroup analysis to compare treatment effects by each sites average INR control level.99 For the 18,024 patients at 906 sites, subgroup analyses were completed by grouping sites into quartiles of time in therapeutic range (TTR). Analyses were adjusted for differences in baseline characteristics across these groups. For the primary outcome of stroke or systemic embolism, there were no significant interactions between TTR and the comparative effects of dabigatran and warfarin. However, the risk of major bleeding was significantly lower for dabigatran 150 mg at sites with poor INR control (TTR <57.1%; test for interaction p = 0.03) but not significantly different from warfarin at sites with better INR control. In contrast, major gastrointestinal bleeding was approximately doubled with dabigatran 150 mg compared to warfarin at sites with better TTR (≥65.5%, p = 0.019). Dabigatran 150 mg was also more effective than warfarin at sites with poor INR control compared with those with good INR control for all vascular events (test for interaction, p = 0.006) and mortality (p = 0.05). In summary, these subgroup analyses suggest that the quality of adjusted-dose warfarin treatment is associated with the comparative effectiveness of dabigatran for several clinically important outcomes.
- In another subgroup analysis that focused on bleeding complications, the effects of dabigatran varied by age.72 In patients under age 75, both doses of dabigatran were associated with a modestly lower risk of major bleeding in comparison to warfarin. In those over age 75, the risk of major bleeding was not significantly different for the 110 mg dose of dabigatran, but the risk approached a statistically significant higher rate for the 150 mg dose compared with warfarin (5.1 versus 4.4%, p = 0.07). Although the risk of bleeding increased with lower creatinine clearance (CrCl), there was no interaction effect between CrCl and the effect of dabigatran. The authors concluded that the observed age effects were not “simply a pharmacokinetic interaction” related to declining CrCl in older adults.
- In a separate analysis of data from the RE-LY study, rates of MI, unstable angina, cardiac arrest, and cardiac death were reported. In the treatment groups on dabigatran 110 mg, 150 mg, and adjusted-dose warfarin, myocardial infarction occurred at an annual rate of 0.82 percent, 0.81 percent, and 0.64 percent (HR 1.29; 95% CI, 0.96 to 1.75; p = 0.09 for dabigatran 110 mg and HR 1.27; CI, 0.94 to 1.71;p = 0.12 for dabigatran 150 mg).84 In conclusion, there was a nonsignificant increase in myocardial infarction with dabigatran treatment while other myocardial events were not increased. The relative effects of dabigatran versus warfarin on myocardial ischemic events were consistent in patients with or without a baseline history of myocardial infarction or coronary artery disease.

#### ROCKET-AF Trial (Rivaroxaban Versus Warfarin)

In the ROCKET-AF trial, the following results were reported:

- A secondary analysis of data from the ROCKET-AF trial evaluated the efficacy and safety of rivaroxaban compared to warfarin in patients with moderate renal dysfunction.83 Around one-fifth of the enrolled population (20.7%) had moderate renal impairment at baseline (CrCl 30–49 mL/min). Compared to patients with CrCl ≥50 mL/min, patients with moderate renal impairment had higher CHADS2 scores and more cardiovascular disease. Patients with moderate renal impairment were treated with a lower dose of rivaroxaban (15 mg/day) than those with better renal function (20 mg/day). For patients with moderate renal dysfunction, the rates of stroke and systemic embolism were higher than in those with CrCl ≥ 50 mL/min, regardless of anticoagulant treatment received. Major bleeding and clinically relevant non–major bleeding occurred more frequently in those with renal insufficiency than in those without, regardless of randomized treatment assigned. Comparative treatment effects for rivaroxaban versus warfarin were similar for all major outcomes, including bleeding events, for those with and without renal insufficiency. When bleeding rates were analyzed further by site of bleeding, patients with impaired renal function who were treated with rivaroxaban had higher gastrointestinal bleeding rates than those treated with warfarin (4.1% versus 2.6%, p = 0.02).

In summary, subgroup analyses show no differential effects on stroke prevention (interaction effects) for individuals with a history of cerebrovascular accidents, impaired renal function, or older age. However, these analyses suggest that some bleeding complications with dabigatran compared with warfarin may be increased in those older than age 75 and at centers with high-quality warfarin treatment. Further, myocardial infarction—but not other myocardial ischemic events—showed a non–statistically significant increase with dabigatran. The effects of impaired renal function were mixed, showing no interaction effect in one analysis and a differential risk of gastrointestinal bleeding with rivaroxaban in another analysis.

## KEY QUESTION 2 For patients with venous thromboembolism, are there differential effects of newer oral anticoagulants versus warfarin or low molecular weight heparins on recurrent thromboembolism, mortality, HRQOL, and patient treatment experience?

We identified three good-quality studies relevant to KQ 2, which involved 8541 patients; all studies were funded by the pharmaceutical industry. These studies evaluated dabigatran (n = 1),85 rivaroxaban (n = 1),89 and ximelagatran (n = 1)86 versus adjusted-dose warfarin. The mean age of participants was between 50 and 55; approximately 56 percent were men. Almost 80 percent of participants had DVT alone, with most of the remainder having both DVT and PE. Average adherence to the intervention drugs was 98 percent in the study evaluating dabigatran,85 and in the study evaluating ximelagatran,89 93 percent of participants took at least 80 percent of prescribed doses. One study did not report adherence.86 In the control groups, the percentage of time in the INR target range was 58 to 61 percent (median 60%). Two studies reported the proportion of time below range (21 to 24%) and above range (16 to 19%).85,86 Studies assessed outcomes at 6 to 12 months; none reported effects on HRQOL or patient experience. Study characteristics are summarized in Table 7.

Table 7 Summary table for KQ 2—venous thromboembolism

Study Characteristic | Number of Studies (Patients)
Total number of studies (patients) | 3 (8541)
Factor Xa inhibitor, dose
Rivaroxaban, 20 mg daily | 1 (3449)
Direct thrombin inhibitors, dose
Dabigatran, 150 mg twice daily | 1 (2564)
Ximelagatran, 36 mg twice daily | 1 (2528)
Study duration:
6 months | 2 (5092)
12 months | 1 (3449)
Mean age
50–60 years | 3 (8541)
60–70 years | –
Sex
Men | 3 (4763)
Women | 3 (3714)
DVT/PE etiology^a^
Idiopathic/unprovoked | 1 (2138), 2 NR
Active cancer | 3 (655)
Prior VTE | 3 (1855)
Adjusted-dose warfarin range
Time above range (%) | 2 (16.2–19%), 1 NR
Time in range (%) | 3 (57.7–61%)
Time below range (%) | 2 (19–21%), 1 NR

a Some subjects may have had more than one risk factor.

Abbreviations: DVT = deep venous thrombosis; NR = not reported; PE = pulmonary embolism; VTE = venous thromboembolism

### Meta-Analyses for KQ 2

We used random-effects model meta-analyses to evaluate the effects of newer oral anticoagulants compared with adjusted-dose warfarin on mortality, risk of recurrent DVT or PE, major bleeding, fatal bleeding, myocardial infarction, liver dysfunction, and drug discontinuation due to adverse effects. There was no statistically significant difference for any of these outcomes. For some outcomes, such as death due to thromboembolism, fatal bleeding, and myocardial infarction, the 95-percent CIs were particularly wide and include the potential for clinically important differences. Tests for heterogeneity suggest variability in treatment effects across studies for recurrent DVT/PE (moderate) and liver dysfunction (high).

There were too few studies to conduct quantitative analyses for factors that may be associated with variable treatment effects. However, a qualitative inspection shows differences across studies in patient characteristics, eligibility criteria, and interventions that may be related to differential treatment effects. Individuals with a previous history of VTE have a 25-percent risk of recurrence in the first 5 years.100 A higher proportion of patients in the dabigatran study 85 had a history of previous VTE than patients in the rivaroxaban study (25 versus 19%).86 The dabigatran study also had a lower threshold to exclude patients for elevations in the alanine transaminase level than for the rivaroxaban study.86 Furthermore, all patients in the dabigatran study received low molecular weight heparin or unfractionated heparin before starting dabigatran, while patients in the rivaroxaban study did not. Low molecular weight heparin and unfractionated heparin can cause liver enzyme elevation.101,102

When the study examining ximelagatran was included, results were similar except that drug discontinuation due to adverse effects was significantly higher than rates with adjusted-dose warfarin. This result appears to be related primarily to higher rates of liver dysfunction with ximelagatran. Summary risk ratios and tests for variability in treatment effects across studies are summarized in Table 8 (Figures 10–14). There were too few studies to conduct subgroup analyses by drug class or statistical tests for publication bias. However, our search of www.clinicalTrials.gov did not suggest publication bias.

Table 8 Effects of newer oral anticoagulants compared with adjusted-dose warfarin for venous thromboembolism

| Summary Risk Ratios (95% CI) | Test for Heterogeneity | Summary Risk Ratios (95% CI) | Test for Heterogeneity
Outcome | Non-ximelagatran studies (n = 2) | | All studies (n = 3)
All-cause mortality | 0.84 (0.59 to 1.18) | Q = 0.47, I^2^ = 0% p = 0.49 | 0.78 (0.59 to 1.02) | Q = 1.01, I^2^ = 0% p = 0.60
Recurrent DVT | 0.66 (0.37 to 1.15) | Q = 1.49, I^2^ = 33% p = 0.22 | 0.72 (0.49 to 1.06) | Q = 2.02, I^2^ = 1% p = 0.36
Death–thromboembolic^a^ | 0.56 (0.19 to 1.69) | Q = 0.28, I^2^ = 0% p = 0.60 | NA | NA
Recurrent DVT/PE | 0.86 (0.55 to 1.33) | Q = 1.79, I^2^ = 44% p = 0.18 | 0.91 (0.67 to 1.24) | Q = 2.43, I^2^ = 18% p = 0.30
Adverse Effect
Discontinued due to adverse effects | 1.19 (0.93 to 1.51) | Q = 1.43, I^2^ = 30% p = 0.23 | 1.24 (1.10 to 1.41) | Q = 1.73, I^2^ = 0% p = 0.42
Major bleeding | 0.77 (0.49 to 1.20) | Q = 0.14, I^2^ = 0% p = 0.71 | 0.69 (0.48 to 0.99) | Q = 0.91, I^2^ = 0% p = 0.63
Fatal bleeding | 0.50 (0.12 to 2.06) | Q = 0.31, I^2^ = 0% p = 0.58 | 0.41 (0.13 to 1.35) | Q = 0.59, I^2^ = 0% p = 0.75
Myocardial infarction | 2.83 (0.75 to 10.71) | Q = 0.44, I^2^ = 0% p =0.51 | 3.46 (1.03 to 11.62) | Q = 0.98, I^2^ = 0% p = 0.61
Liver dysfunction | 0.60 (0.27 to 1.34) | Q = 6.80, I^2^ = 85% p = 0.009 | 1.20 (0.29 to 4.98) | Q = 65.83, I^2^ = 97% p < 0.001

a No data for ximelagatran group.

b Fiessenger 2005 did not report thromboembolic death

Abbreviations: DVT = deep venous thrombosis; NA = not applicable; PE = pulmonary embolism

#### Forest Plots for Studies Without Ximelagatran (Venous Thromboembolism)

Figure 10 VTE: All-cause mortality without ximelagatran^a^

Figure 11 VTE: Death–thromboembolic without ximelagatran^a,b^

Figure 12 VTE: Recurrent DVT/PE without ximelagatran^a^ a The study evaluating ximelagatran is shown but not incorporated into the summary risk ratio in Figures 10, 11, and 12.

b Fiessenger 2005 did not report thromboembolic death.

#### Forest Plots for Studies With Ximelagatran (Venous Thromboembolism)

Figure 13 VTE: All-cause mortality with ximelagatran

NOTE: NO Forest Plot for VTE: Death–thromboembolic with ximelagatran.

There were no data on this outcome for the ximelagatran group.

Figure 14 VTE: Recurrent DVT/PE with ximelagatran

## KEY QUESTION 3 For patients with mechanical heart valves, what is the comparative effectiveness of newer anticoagulants versus warfarin on the incidence of thromboembolic complications, mortality, HRQOL, and patient treatment experience?

We did not identify any published studies that compared newer anticoagulants to adjusted-dose warfarin in patients with mechanical heart valves. We identified one ongoing trial from our search of www.clinicaltrials.gov (Appendix F).

## KEY QUESTION 4 When used for long-term anticoagulation treatment, what is the nature and frequency of adverse effects for newer anticoagulants versus warfarin?

We reported the risks of adverse effects separately in KQ 1 and KQ 2 for each treatment indication. In this section, we examine the risk of adverse effects for all included randomized controlled trials and supplement this by a review of observational studies and FDA alerts. For the analysis of trial data, we examined the summary risk ratios, first in all studies and then by drug class. We excluded studies of ximelagatran for this analysis because this drug has been withdrawn from the market due to adverse effects on liver function.

The range of adverse effect rates for newer oral anticoagulants in the chronic AF studies and VTE studies, respectively, were discontinued due to adverse effects (6.2% to 8.3%; 4.9% to 9.0%); major bleeding (3.6% to 6.2%; 0.8% to 1.6%); fatal bleeding (0.1% to 0.4%; 0.1% reported in one study); myocardial infarction (1.0% to 1.5%; 0.3% reported in one study); and liver dysfunction (0.5% to 1.9%; 1.5% to 3.4%). Compared with the VTE studies, the studies in patients with chronic AF included older patients who may have had more chronic medical conditions and concurrent medications, increasing the risk for adverse effects.94 In addition, the treatment duration was longer for the chronic AF studies, which may also increase the absolute rates of adverse effects.

The newer oral anticoagulants were associated with a consistent decrease in mortality (0.88; 95% CI, 0.82 to 0.95), without significant variability across studies or differences between drug classes. Similarly, rates of fatal bleeding were consistently lower with newer oral anticoagulants (Table 9). There was a non–statistically significant reduction in major bleeding, but this effect varied importantly across studies—variability that was not explained by drug class. The unexplained variability in effect for this outcome and others with similar findings suggests the possibility of important differences between individual drugs, even within drug class. The risk of gastrointestinal bleeding was increased with newer oral anticoagulants, with significant variability across studies that was not explained by drug class. Overall, the risk of myocardial infarction was not different from adjusted-dose warfarin. When analyzed by drug class, the risk of myocardial infarction was higher with DTIs than with FXa inhibitors. Drug discontinuation due to adverse effects showed a small, non–statistically significant increased risk ratio, but the risk of discontinuation varied substantially across studies. When analyzed by drug class, DTIs had a higher risk of drug discontinuation compared with FXa inhibitors. The risk of liver dysfunction, an adverse effect that led to the withdrawal of ximelagatran from the market, was not increased.

Table 9 Risk of mortality and adverse effects overall and by drug class

| All studies (n = 5) | | Comparison by Drug Class
Adverse Effect | Summary Risk Ratios (95% CI) | Tests for Heterogeneity | Summary Risk Ratios (95% CI) | Test for differences between drug classes
All-cause mortality | 0.88 (0.82 to 0.95) | Q = 1.05, I^2^ = 0% p < 0.90 | DTI: 0.90 (0.79 to 1.01) FXa: 0.88 (0.80 to 0.96) | p = 0.77
Discontinued due to adverse effects | 1.23 (0.94 to 1.61) | Q = 57.96, I^2^ = 93% p < 0.001 | DTI: 1.61 (1.14 to 2.27) FXa: 1.04 (0.84 to 1.28) | p = 0.03
Major bleeding | 0.86 (0.71 to 1.04) | Q = 16.08, I^2^ = 75% p = 0.003 | DTI: 0.93 (0.82 to 1.06) FXa: 0.83 (0.60 to 1.14) | p = 0.49
Fatal bleeding | 0.59 (0.46 to 0.77) | Q = 1.57, I^2^ = 0% p = 0.81 | DTI: 0.72 (0.45 to 1.16) FXa: 0.55 (0.40 to 0.75) | p = 0.35
Gastrointestinal bleeding | 1.30 (1.01 to 1.68) | Q=12.04, I^2^ = 75% p = 0.007 | DTI: 1.50 (1.24 to 1.80) FXa: 1.14 (0.69 to 1.87) | p = 0.05
Myocardial infarction^a^ | 1.02 (0.76 to 1.39) | Q = 9.37, I^2^ = 57% p = 0.05 | DTI: 1.35 (0.99 to 1.85) FXa: 0.86 (0.66 to 1.11) | p = 0.03
Liver dysfunction | 0.82 (0.61 to 1.11) | Q = 14.48, I^2^ = 72% p = 0.006 | DTI: 0.88 (0.72 to 1.09) FXa: 0.76 (0.41 to 1.42) | p = 0.65

a Only four studies reported this outcome.

Abbreviations: CI = confidence interval; NA = not applicable

### Forest Plots for Studies Without Ximelagatran (Adverse Effects)

Figure 15 Adverse effects: All-cause mortality without ximelagatran

Figure 16 Adverse effects: Discontinued due to adverse effects without ximelagatran

Figure 17 Adverse effects: Major bleeding without ximelagatran

Figure 18 Adverse effects: Fatal bleeding without ximelagatran

Figure 19 Adverse effects: Gastrointestinal bleeding without ximelagatran

Figure 20 Adverse effects: Myocardial infarction without ximelagatran

Figure 21 Adverse effects: Liver dysfunction without ximelagatran

## RESULTS FROM OBSERVATIONAL STUDIES

We reviewed 377 observational studies on adverse effects of newer oral anticoagulants and excluded 349 on the basis of our inclusion/exclusion criteria. We performed a full-text review on the remaining 28 studies and included 10 of these for data abstraction. Three of the 10 were subgroup analyses from included RCTs and have been discussed previously under KQ 1. Seven of the 10 were case studies, and one was a systematic review. These are discussed below by major outcome.

### Bleeding

Three case reports described bleeding associated with dabigatran treatment; one of these was in the context of concurrent use of a thrombolytic medication.

#### Splenic hemorrhage

A 78-year-old woman presented to the emergency department with acute-onset abdominal pain and vomiting. She had a past medical history of stroke secondary to AF and had been switched 1 week earlier from warfarin to dabigatran 100 mg orally twice daily for thromboprophylaxis. She denied any history of trauma. A computed tomography (CT) scan revealed extravasation from the posterior aspect of the spleen and hemoperitoneum.81

#### Cerebral hemorrhage after concurrent thrombolytic treatment

A 62-year-old diabetic male was started on dabigatran 110 mg twice daily following cardioversion for nonvalvular AF. Following the third dose of dabigatran, he developed aphasia and right hemiplegia. A CT scan revealed a perfusion deficit in the left middle cerebral artery area and no evidence of intracranial hemorrhage. All of his coagulation test values were within normal limits apart from a borderline high prothrombin time. He was started on thrombolytic therapy and 12 hours later became comatose. A brain CT scan showed a lobar hemorrhage with mass effect. The patient died 2 days later.77

#### Gastrointestinal bleeding and epistaxis

Legrand et al. reported two cases of bleeding in elderly patients on dabigatran treatment.79 The first case was an 84-year-old woman who had been on dabigatran 75 mg twice daily for AF for a period of 4 months prior to presentation. She presented with rectal bleeding associated with a fecaloma. Her CrCl was 32 mL/min and her body weight was 40 kg. She developed a massive rectal hemorrhage after digital evacuation of the fecaloma and died of hemorrhagic shock despite resuscitation and transfusion of blood and fresh frozen plasma. The trough plasma concentration of dabigatran was very high (5600 ng/mL; expected range, 31–225 ng/mL). The second case was an 89-year-old woman (weight 45 kg), who was given dabigatran 110 mg twice daily for prevention of stroke in AF. At presentation for a scheduled procedure 5 months after starting on dabigatran, she reported recurrent episodes of epistaxis of 1 week duration. Preoperative laboratory evaluation revealed anemia, prolonged baseline coagulation studies, and elevated dabigatran plasma concentration (2670 ng/mL). Her CrCl was low at 29 mL/min. Her procedure was cancelled and dabigatran was discontinued with a favorable outcome.

### Thrombosis

Two case reports described ischemic stroke in patients taking dabigatran and successful treatment with thrombolytic medication.

#### Ischemic stroke

One study reported a 48-year-old woman with an acute onset of left-sided hemiplegia and hemihypesthesia, who was found to have an ischemic stroke in the area of the right middle cerebral artery.78 The patient had a history of AF and was randomized to dabigatran on the RELYABLE study (NCT00808067). She was started on thrombolytic therapy with recombinant tissue plasminogen activator almost 7 hours after her last dose of dabigatran. All coagulation tests were within normal limits, apart from fibrinogen, which was borderline high. The patient improved and suffered no complications.

Another study reported a 76-year-old woman with a history of diabetes and hypertension, who presented with acute right-sided hemiplegia and aphasia.80 The patient was on dabigatran 220 mg once daily as thromboprophylaxis following knee replacement therapy. She was started on thrombolytic therapy 15 hours following her last dose of dabigatran. Treatment was completed successfully with no bleeding complications.

### Myocardial Infarction

We identified a single systematic review that addressed adverse effects for newer oral anticoagulants. This review of seven mostly short-term trials evaluated dabigatran for heterogeneous indications and found a higher risk of myocardial infarction or acute coronary syndrome (OR 1.33; 95% CI, 1.03 to 1.71) compared with warfarin, enoxaparin, or placebo.70

We did not identify any primary reports of observational studies evaluating MI.

### Mechanical Valve Thrombosis

Clinical experience is currently limited as to the efficacy and safety of the newer oral anticoagulants for thromboprophylaxis in patients with prosthetic valves. As noted in KQ 3, no trials have published outcomes for this indication. We identified a single case report of anticoagulation failure with dabigatran. A 62-year-old man with a bileaflet mechanical aortic valve (St. Jude Medical) and a history of AF was switched, upon his request, from warfarin to dabigatran 150 mg twice daily for thromboprophylaxis.82 Eleven months later, he presented with facial droop and hemiparesis, which resolved over 24 hours. An MRI study of the patient’s brain showed multiple cerebral ischemic infarcts, and later a transesophageal echocardiogram showed a thrombus on the posterior disc of the prosthetic aortic valve. Dabigatran was stopped, and the patient was started on phenindione with 100 mg aspirin. A followup transesophageal echocardiogram showed disappearance of the thrombus.

## SUMMARY OF FDA BULLETINS

QuarterWatch is a nonprofit Federally certified Institute for Safe Medication Practice, which monitors adverse events reported to the FDA through MedWatch. On October 6, 2011, a report by QuarterWatch stated that, within months of its release, dabigatran generated more reports (307) than 98.7 percent of other drugs monitored. Reported adverse events were equally divided between hemorrhagic and thrombotic events. Only 36 percent of reports listed that dabigatran was used for its approved indications. Another 46 percent reported that the drug was used to prevent blood clots or stroke in general terms. Furthermore, other reports clearly stated the drug was used for off-label indications such as thromboprophylaxis after orthopedic surgery.103

On January 12, 2012, QuarterWatch released a report of serious adverse events linked to dabigatran. During the first quarter of 2011, 932 serious adverse events were linked to dabigatran, including 120 deaths, 25 permanent disabilities, and 543 hospitalizations. Of the 932 cases, 505 involved hemorrhage—more than any other monitored drug, including warfarin. The adverse events occurred in elderly patients with a median age of 80 years, compared with 56 years in all other monitored drugs. The report raised questions about using a fixed dose for all patient populations. Older age and impaired renal function lead to a longer half-life and higher drug levels. Currently, dosage adjustment is recommended for only patients with severe renal impairment. However, mild and moderate renal impairment can increase dabigatran levels by 50 percent and 300 percent, respectively. The report recommends that the FDA and the manufacturer reevaluate the dose of dabigatran for elderly patients and those with moderate renal impairment.104

The FDA Advisory Committee Briefing Document on adverse events associated with rivaroxaban reported that, in the ROCKET-AF study, the posttreatment discontinuation events were higher in patients on rivaroxaban (12.63 per 100 patient years) compared with patients on adjusted-dose warfarin (8.36 per 100) (HR 1.51; 95% CI, 1.02 to 2.23). This higher event rate may be due to fewer patients transitioning from rivaroxaban to warfarin having a therapeutic INR during the period of 3 to 30 days after treatment. This finding points to the need for particular care when transitioning patients from short-acting newer oral anticoagulants to warfarin.