# CRITERIA USED IN QUALITY ASSESSMENT

Quality assessment form

Table G-1 Quality assessment of the included studies

Quality Item | Albers et al., 2005 | Bauersachs et al., 2010 | Connolly et al., 2009 | Fiessinger et al., 2005 | Granger et al., 2011 | Olsson et al., 2003 | Patel et al., 2011 | Schulman et al., 2009
Randomization adequate? | Yes | Yes | Yes | Yes | NR/unclear | Yes | Yes | Yes
Allocation concealment? | Yes | Yes | Yes | Yes | No | Yes | NR/unclear | Yes
Outcome assessors blinded? (hard outcomes) | Yes | Yes | NR/unclear | Yes | Yes | Yes | Yes | Yes
Outcome assessor blinded? (soft outcomes) | Yes | Yes | NR/unclear | Yes | Yes | Yes | Yes | Yes
Lack of measurement bias? | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
All outcomes reported? | Yes | Yes | Yes | NR/unclear | Yes | Yes | Yes | Yes
Incomplete outcome data adequately addressed? | Yes | NR/unclear | Yes | Yes | Yes | Yes | No | Yes
Adequate power for main effects? | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Other selection bias? | No | No | No | Yes | No | No | No | No
Comparable groups maintained? | Yes | Yes | Yes | NR/unclear | Yes | Yes | Yes | Yes
Absence of potential important conflict of interest? | No | No | No | No | No | No | No | No
Overall rating | Good | Good | Good | Good | Good | Good | Good | Good

Abbreviation: NR = not reported