# ONGOING CLINICAL TRIALS

Table F-1 Ongoing RCTs of atrial fibrillation interventions (KQ 1)

Study title | VA/DoD population? | Intervention | Comparator | Sponsor and ClinicalTrials.gov ID | Funding Start/Stop | Status
Long-Term Safety in Atrial Fibrillation Patients | No | AZD0837 | Vitamin K antagonists (warfarin) | AstraZeneca NCT00645853 | Oct 2007–May 2009 | Completed
RELY-ABLE Long Term Multicenter Extension of Dabigatran Treatment in Patients With Atrial Fibrillation Who Completed RE-LY Trial | No | Dabigatran dose 1 high dose twice daily | Dabigatran dose 2 low dose twice daily | Boehringer Ingelheim Pharmaceuticals NCT00808067 | Nov 2008–Apr 2013 | Ongoing, not recruiting
The IMPACT of BIOTRONIK Home Monitoring Guided Anticoagulation on Stroke Risk in Patients With Implanted ICD and CRT-D Devices | No | Dabigatran etexilate, warfarin | Dabigatran etexilate, warfarin | Biotronik NCT00559988 | Feb 2008–Feb 2015 | Recruiting
Direct Factor Xa Inhibitor YM150 for Prevention of Stroke in Subjects With Non- Valvular Atrial Fibrillation | No | YM150 | Warfarin | Astellas Pharma Inc. NCT00448214 | Mar 2007–Oct 2008 | Completed

Table F-2 Ongoing RCTs of venous thromboembolism interventions (KQ 2)

Study title | VA/DoD population? | Intervention | Comparator | Sponsor and ClinicalTrials.gov ID | Funding Start/Stop | Status
Phase III Study Testing Efficacy & Safety of Oral Dabigatran Etexilate vs Warfarin for 6 m Treatment for Acute Symp VTE | No | Dabigatran etexilate | Warfarin | Boehringer Ingelheim Pharmaceuticals NCT00680186 | Apr 2008–May 2011 | Completed, recent
Secondary Prevention of Venous Thrombo Embolism (VTE) | No | Dabigatran | Warfarin | Boehringer Ingelheim Pharmaceuticals NCT00329238 | May 2006–Oct 2010 | Completed, abstract presented, but no publication to date
Oral Direct Factor Xa Inhibitor Rivaroxaban In Patients With Acute Symptomatic Pulmonary Embolism With Or Without Symptomatic Deep-Vein Thrombosis: Einstein-PE Evaluation | No | Xarelto (rivaroxaban, BAY59-7939) | Enoxaparin followed by vitamin K antagonist | Bayer NCT00439777 | Mar 2007–Oct 2011 | Completed, recent
Comparative Investigation of Low Molecular Weight (LMW) Heparin/Edoxaban Tosylate (DU176b) vs. LMW Heparin/ Warfarin in the Treatment of Symptomatic Deep-Vein Blood Clots and/or Lung Blood Clots. | No | LMW Heparin/ Edoxaban | LMW Heparin/ Warfarin | Daiichi Sankyo Inc. NCT00986154 | Oct 2009–Sep 2012 | Recruiting Methods paper published

Table F-3 Ongoing RCTs of mechanical heart valve interventions (KQ 3)

Study title | VA/DoD population? | Intervention | Comparator | Sponsor and ClinicalTrials.gov ID | Funding Start/Stop | Status
Dabigatran Etexilate in Patients With Mechanical Heart Valves | No | Dabigatran etexilate | Warfarin | Boehringer Ingelheim Pharmaceuticals NCT01452347 | Oct 2011–Aug 2012 | Recruiting
A Safety and Efficacy Trial Evaluating the Use of Apixaban in the Treatment of Symptomatic Deep Vein Thrombosis and Pulmonary Embolism | No | Placebo for enoxaparin Placebo for warfarin Apixaban | Active comparator: Enoxaparin Warfarin Placebo for apixaban | Bristol-Myers Squibb NCT00643201 | July 2008–Mar 2013 | Recruiting
A Phase 3, Randomized, Double-Blind, Double-Dummy, Parallel Group, Multi-Center, Multi-National Study for Evaluation of Efficacy and Safety of DU-176b Versus Warfarin In Subjects With Atrial Fibrillation - Effective Anticoagulation With Factor Xa Next Generation in Atrial Fibrillation (ENGAGE - AF TIMI - 48) | No | DU-176b plus warfarin placebo tablets | Warfarin tablets plus DU-176b | Daiichi Sankyo Inc. NCT00781391 | Nov 2008–Feb 2012 | Ongoing; methods paper published
Long-term, Open-label Follow-up Treatment of Patients With A-fib Who Have Been Previously Treated with BIBR 1048 | No | Dabigatran | None-open label, nonrandomized Phase II study | Boehringer Ingelheim Pharmaceutical NCT00157248 | Dec 2003–Jan 2009 | Terminated; has results