# SAMPLE DATA EXTRACTION FORMS

Elements abstracted from RCTs

Form 2 Baseline Characteristics

Form 3a Atrial Fibrillation

Form 3b VTE

Form 4a Outcome Measures Reported

Form 4b Outcome Measures Reported

Form 5 Adverse Event Outcomes