# EXCLUDED STUDIES

All citations listed in Tables C-1 and C-2 were reviewed in their full-text version and excluded for the reason indicated. An alphabetical reference list follows each table.

## Excluded RCTs

Table C-1 Excluded RCTs with reasons

Reference | Not full publication, peer-reviewed, or primary data | Not study population of interest | New drug or comparator not of interest | No relevant outcomes reported at ≥6 months
Adams 2005 | X
Ageno 2005 | X
Agnelli 2009 | | X
Amadeus Investigators 2008 | | | X
Anonymous 2004 | X
Anonymous 2009 | X
Berry 2005 | X
Botticelli Investigators 2008 | | | | X
Buller 2007 | | | X
Buller 2007 | | | X
Buller 2007 | | | X
Camm 2009 | X
Chung 2011 | | | | X
Cohen 2006 | | X
Connolly 2011 | | | X
Connolly 2010 | X
Dahl 2010 | X
Deitcher 2006 | | | X
EAFT Study Group 1993 | | | X
Eriksson 2005 | | | X
Eriksson 2003 | | | | X
Fiessinger 1996 | | | X
Halperin 2005 | X
Halperin 2005 | X
Hankey 2004 | X
Hankey 2009 | X
Hankey 2011 | X
Harenberg 2002 | X
Hart 1999 | | | X
Heidbuchel 2010 | X
Hull 2006 | | | X
Kaul 2005 | X
Kubitza 2006 | X
Kwok 2004 | X
Lee 2003 | | | X
Lip 2009 | | | | X
Lopez-Beret 2001 | | | X
Meyer 2002 | | | X
Olsson 2010 | | | | X
Paikin 2011 | X
Party 2010 | | | X
Persist Investigators 2004 | | | | X
Petersen 2003 | | | | X
Prandoni 2010 | X
Prins 2009 | | | X
Rother 2010 | X
Salam 2004 | X
Schulman 2005 | | | X
Segal 2001 | | | X
SPIAF Investigators 1996 | | | X
SPIAF Investigators 1991 | | | X
Taylor 2001 | | | X
Wahlander 2006 | | | X
Wallentin 2010 | X
Weitz 2010 | | | | X
Weitz 2010 | | | | X

Abbreviations: EAFT = European Atrial Fibrillation Trial; SPIAF = Stroke Prevention in Atrial Fibrillation

### LIST OF EXCLUDED RCTs

Adams HP. Prevention of embolism among patients with atrial fibrillation. Curr Neurol Neurosci Rep. 2005;5(1):9-12. [pmid: 15676102].
Ageno W, Turpie AG. Clinical trials of deep vein thrombosis prophylaxis in medical patients. Clin Cornerstone. 2005;7(4):16-22. [pmid: 16758648].
Agnelli G, Eriksson BI, Cohen AT, et al. Safety assessment of new antithrombotic agents: lessons from the EXTEND study on ximelagatran. Thromb Res. 2009;123(3):488-97. [pmid: 18485453].
Amadeus Investigators. Comparison of idraparinux with vitamin K antagonists for prevention of thromboembolism in patients with atrial fibrillation: a randomised, open-label, non-inferiority trial. The Lancet. 2008;371(9609):315-321.
Results of THRIVE treatent study show that ximelagatran is safe and effective against throbosis. J Support Oncol. 2004;2(1):56. [pmid: 15330373].
Dabigatran: safer, more effective and easier to use than warfarin. Cardiovasc J Afr. 2009;20(5):311-2. [pmid: 19907807].
Berry C, Norrie J, McMurray JJ. Ximelagatran compared with warfarin for the prevention of systemic embolism and stroke. An imputed placebo analysis. Cardiovasc Drugs Ther. 2005;19(2):149-51. [pmid: 16025234].
Botticelli Investigators. Efficacy and safety of the oral direct factor Xa inhibitor apixaban for symptomatic deep vein thrombosis. The Botticelli DVT dose-ranging study. Journal of thrombosis and haemostasis : JTH. 2008:1313-8. [pmid: 18541000].
Buller HR, Cohen AT, Davidson B, et al. Idraparinux versus standard therapy for venous thromboembolic disease. New England Journal of Medicine. 2007;357(11):1094-1104. [pmid: 17855670].
Buller HR, Cohen AT, Davidson B, et al. Extended prophylaxis of venous thromboembolism with idraparinux. New England Journal of Medicine. 2007;357(11):1105-1112. [pmid: 17855671].
Buller HR, Cohen AT, Davidson B, et al. Idraparinux versus standard therapy for venous thromboembolic disease. N Engl J Med. 2007;357(11):1094-104. [pmid: 17855670].
Camm AJ. The RE-LY study: Randomized Evaluation of Long-term anticoagulant therapY: Dabigatran vs. warfarin. European Heart Journal. 2009;30(21):2554-2555. [pmid: 19770196].
Chung N, Jeon HK, Lien LM, et al. Safety of edoxaban, an oral factor Xa inhibitor, in Asian patients with non-valvular atrial fibrillation. Thromb Haemost. 2011;105(3):535-44. [pmid: 21136011].
Cohen AT, Davidson BL, Gallus AS, et al. Efficacy and safety of fondaparinux for the prevention of venous thromboembolism in older acute medical patients: randomised placebo controlled trial. BMJ. 2006;332(7537):325-327. [pmid: 16439370].
Connolly SJ, Eikelboom J, Joyner C, et al. Apixaban in patients with atrial fibrillation. N Engl J Med. 2011;364(9):806-17. [pmid: 21309657].
Connolly SJ, Ezekowitz MD, Yusuf S, et al. Newly identified events in the RE-LY trial. N Engl J Med. 2010;363(19):1875-6. [pmid: 21047252].
Dahl OE, Huisman MV. Dabigatran etexilate: advances in anticoagulation therapy. Expert Rev Cardiovasc Ther. 2010;8(6):771-4. [pmid: 20528634].
Deitcher SR, Kessler CM, Merli G, et al. Secondary prevention of venous thromboembolic events in patients with active cancer: enoxaparin alone versus initial enoxaparin followed by warfarin for a 180-day period. Clin Appl Thromb Hemost. 2006;12(4):389-96. [pmid: 17000884].
EAFT (European Atrial Fibrillation Trial) Study Group. Secondary prevention in non-rheumatic atrial fibrillation after transient ischaemic attack or minor stroke. Lancet. 1993;342(8882):1255-62. [pmid: 7901582].
Eriksson H, Lundstrom T, Wahlander K, et al. Prognostic factors for recurrence of venous thromboembolism (VTE) or bleeding during long-term secondary prevention of VTE with ximelagatran. Thromb Haemost. 2005;94(3):522-7. [pmid: 16268466].
Eriksson H, Wahlander K, Gustafsson D, et al. A randomized, controlled, dose-guiding study of the oral direct thrombin inhibitor ximelagatran compared with standard therapy for the treatment of acute deep vein thrombosis: THRIVE I. J Thromb Haemost. 2003;1(1):41-7. [pmid: 12871538].
Fiessinger JN, Lopez-Fernandez M, Gatterer E, et al. Once-daily subcutaneous dalteparin, a low molecular weight heparin, for the initial treatment of acute deep vein thrombosis. Thromb Haemost. 1996;76(2):195-9. [pmid: 8865530].
Halperin JL. Anticoagulation for atrial fibrillation in the elderly. Am J Geriatr Cardiol. 2005;14(2):81-6. [pmid: 15785149].
Halperin JL. Ximelagatran: oral direct thrombin inhibition as anticoagulant therapy in atrial fibrillation. J Am Coll Cardiol. 2005;45(1):1-9. [pmid: 15629364].
Hankey GJ. At last, a RE-LYable alternative to warfarin for atrial fibrillation. Int J Stroke. 2009;4(6):454-5. [pmid: 19930055].
Hankey GJ, Eikelboom JW. Dabigatran etexilate: a new oral thrombin inhibitor. Circulation. 2011;123(13):1436-50. [pmid: 21464059].
Hankey GJ, Klijn CJ, Eikelboom JW. Ximelagatran or warfarin for stroke prevention in patients with atrial fibrillation?. Stroke. 2004;35(2):389-91. [pmid: 14757889].
Harenberg J, Ingrid J, Tivadar F. Treatment of venous thromboembolism with the oral thrombin inhibitor, ximelagatran. Isr Med Assoc J. 2002;4(11):1003-5. [pmid: 12489490].
Hart RG, Benavente O, McBride R, et al. Antithrombotic therapy to prevent stroke in patients with atrial fibrillation: a meta-analysis. Ann Intern Med. 1999;131(7):492-501. [pmid: 10507957].
Heidbuchel H, Verhamme P. Dabigatran for stroke prevention in atrial fibrillation: from RE-LY to daily clinical practice. Acta Cardiol. 2010;65(5):491-7. [pmid: 21125969].
Hull RD, Pineo GF, Brant RF, et al. Long-term low-molecular-weight heparin versus usual care in proximal-vein thrombosis patients with cancer. Am J Med. 2006;119(12):1062-72. [pmid: 17145251].
Kaul S, Diamond GA, Weintraub WS. Trials and tribulations of non-inferiority: the ximelagatran experience. J Am Coll Cardiol. 2005;46(11):1986-95. [pmid: 16325029].
Kubitza D, Haas S. Novel factor Xa inhibitors for prevention and treatment of thromboembolic diseases. Expert Opin Investig Drugs. 2006;15(8):843-55.
Kwok L, Boucher M. Ximelagatran for prevention and treatment of venous thromboembolism. Issues Emerg Health Technol. 2004;(57):1-4. [pmid: 15214359].
Lee AY, Levine MN, Baker RI, et al. Low-molecular-weight heparin versus a coumarin for the prevention of recurrent venous thromboembolism in patients with cancer. N Engl J Med. 2003;349(2):146-53. [pmid: 12853587].
Lip GY, Rasmussen LH, Olsson SB, et al. Oral direct thrombin inhibitor AZD0837 for the prevention of stroke and systemic embolism in patients with non-valvular atrial fibrillation: a randomized dose-guiding, safety, and tolerability study of four doses of AZD0837 vs. vitamin K antagonists. Eur Heart J. 2009;30(23):2897-907. [pmid: 19690349].
Lopez-Beret P, Orgaz A, Fontcuberta J, et al. Low molecular weight heparin versus oral anticoagulants in the long-term treatment of deep venous thrombosis. J Vasc Surg. 2001;33(1):77-90. [pmid: 11137927].
Meyer G, Marjanovic Z, Valcke J, et al. Comparison of low-molecular-weight heparin and warfarin for the secondary prevention of venous thromboembolism in patients with cancer: a randomized controlled study. Arch Intern Med. 2002;162(15):1729-35. [pmid: 12153376].
Olsson SB, Rasmussen LH, Tveit A, et al. Safety and tolerability of an immediate-release formulation of theoral direct thrombin inhibitor AZD0837 in the prevention of stroke and systemic embolism in patients with atrial fibrillation. Thromb Haemost. 2010;103(3):604-12. [pmid: 20076850].
Paikin JS, Haroun MJ, Eikelboom JW. Dabigatran for stroke prevention in atrial fibrillation: the RE-LY trial. Expert Rev Cardiovasc Ther. 2011;9(3):279-86. [pmid: 21438804].
Paty I, Trellu M, Destors JM, et al. Reversibility of the anti-FXa activity of idrabiotaparinux (biotinylated idraparinux) by intravenous avidin infusion. J Thromb Haemost. 2010;8(4):722-9. [pmid: 20088937].
Persist Investigators. A novel long-acting synthetic factor Xa inhibitor (SanOrg34006) to replace warfarin for secondary prevention in deep vein thrombosis. A Phase II evaluation. J Thromb Haemost. 2004;2(1):47-53. [pmid: 14717965].
Petersen P, Grind M, Adler J. Ximelagatran versus warfarin for stroke prevention in patients with nonvalvular atrial fibrillation. SPORTIF II: a dose-guiding, tolerability, and safety study. J Am Coll Cardiol. 2003;41(9):1445-51. [pmid: 12742279].
Prandoni P, Taher A. Insights from the dabigatran versus warfarin trial in patients with venous thromboembolism (the RE-COVER trial). Expert Opin Pharmacother. 2010;11(6):1035-7. [pmid: 20307227].
Prins MH, Guillemin I, Gilet H, et al. Scoring and psychometric validation of the Perception of Anticoagulant Treatment Questionnaire (PACT-Q(copyright)). Health and Quality of Life Outcomes. 2009;7.
Rother J, Crijns H. Prevention of stroke in patients with atrial fibrillation: the role of new antiarrhythmic and antithrombotic drugs. Cerebrovasc Dis. 2010;30(3):314-22. [pmid: 20664267].
Salam AM. Ximelagatran for stroke prevention in atrial fibrillation. Therapy. 2004:49-52.
Schulman S, Lundstrom T, Walander K, et al. Ximelagatran for the secondary prevention of venous thromboembolism: a complementary follow-up analysis of the THRIVE III study. Thromb Haemost. 2005;94(4):820-4. [pmid: 16270637].
Segal JB, McNamara RL, Miller MR, et al. Anticoagulants or antiplatelet therapy for non-rheumatic atrial fibrillation and flutter. Cochrane Database of Systematic Reviews. 2001;(1).
Stroke Prevention in Atrial Fibrillation Investigators. Stroke Prevention in Atrial Fibrillation Study Final Results. Circulation. 1991;84(2):527-39. [pmid: 1860198].
Stroke Prevention in Atrial Fibrillation Investigators. Bleeding During Antithrombotic Therapy in Patients With Atrial Fibrillation. Arch Intern Med. 1996;156(4):409-16. [pmid: 8607726].
Taylor FC, Cohen H, Ebrahim S. Systematic review of long term anticoagulation or antiplatelet treatment in patients with non-rheumatic atrial fibrillation. BMJ. 2001;322(7282):321-6. [pmid: 11159653].
Wahlander K, Eriksson H, Lundstrom T, et al. Risk of recurrent venous thromboembolism or bleeding in relation to thrombophilic risk factors in patients receiving ximelagatran or placebo for long-term secondary prevention of venous thromboembolism. British Journal of Haematology. 2006:68-77. [pmid: 16512831].
Wallentin L, Ezekowitz MD, Eikelboom J, et al. Efficacy and safety of dabigatran compared to warfarin at different levels of INR control for stroke prevention in 18,113 patients with atrial fibrillation in the RE-LY trial. Circulation. 2010;120(21):2158.
Weitz JI, Cao C, Eriksson BI, et al. A dose-finding study with TAK-442, an oral factor Xa inhibitor, in patients undergoing elective total knee replacement surgery. Thromb Haemost. 2010;104(6):1150-7. [pmid: 20886185].
Weitz JI, Connolly SJ, Patel I, et al. Randomised, parallel-group, multicentre, multinational phase 2 study comparing edoxaban, an oral factor Xa inhibitor, with warfarin for stroke prevention in patients with atrial fibrillation. Thromb Haemost. 2010;104(3):633-41. [pmid: 20694273].

## Excluded Observational Studies

Table C-2 Excluded observational studies

Reference | Background only | Not full publication | Not study population of interest | No relevant outcomes (adverse effects) reported at >2 weeks from drug initiation | Not good quality
Aalbers 2010 | X
Anonymous 2011 | | X
Baruch 2011 | | | X
Beyer-Westendorf 2011 | X
Bovio 2011 | X
Camm 2009 | | X
Coleman 2012 | | | | | X
Cotton 2011 | X
Eerenberg 2011 | X
Gerotziafas 2005 | | | | X
Jacobs 2012 | X
Kaeberich 2011 | | | X
Lip 2010
Loke 2011 | X
McKellar 2011 | | | X
Poultside 2012 | | | X
Roskell 2010 | | | | | X
Tzeis 2011 | X
Watanabe 2012 | | X

### LIST OF EXCLUDED OBSERVATIONAL STUDIES

Aalbers J. Rivaroxaban equals warfarin treatment in atrial fibrillation patients at high risk of stroke. Cardiovasc J Afr. 2010;21(6):342-3. [pmid: 21135986].
New insights and results from the RE-LY trial. Cardiovasc J Afr. 2011;22(5):284-6. [pmid: 21983958].
Baruch L, Sherman O. Potential inaccuracy of point-of-care INR in dabigatran-treated patients. Ann Pharmacother. 2011;45(7–8):e40. [pmid: 21712509].
Beyer-Westendorf J, Buller H. External and internal validity of open label or double-blind trials in oral anticoagulation: better, worse or just different?. J Thromb Haemost. 2011;9(11):2153-8. [pmid: 21920015].
Bovio JA, Smith SM, Gums JG. Dabigatran etexilate: a novel oral thrombin inhibitor for thromboembolic disease. Ann Pharmacother. 2011;45(5):603-14. [pmid: 21540406].
Camm. Dabigatran: safer, more effective and easier to use than warfarin. Cardiovasc J Afr. 2009;20(5):311-2. [pmid: 19907807].
Coleman CI, Sobieraj DM, Winkler S, et al. Effect of pharmacological therapies for stroke prevention on major gastrointestinal bleeding in patients with atrial fibrillation. Int J Clin Pract. 2012;66(1):53-63. [pmid: 22093613].
Cotton BA, McCarthy JJ, Holcomb JB. Acutely injured patients on dabigatran. N Engl J Med. 2011;365(21):2039-40. [pmid: 22111735].
Eerenberg ES, Kamphuisen PW, Sijpkens MK, et al. Reversal of rivaroxaban and dabigatran by prothrombin complex concentrate: a randomized, placebo-controlled, crossover study in healthy subjects. Circulation. 2011;124(14):1573-9. [pmid: 21900088].
Gerotziafas GT, Samama MM. Heterogeneity of synthetic factor Xa inhibitors. Curr Pharm Des. 2005;11(30):3855-76. [pmid: 16305517].
Jacobs JM, Stessman J. Dabigatran: Do We Have Sufficient Data?: Comment on “Dabigatran Association With Higher Risk of Acute Coronary Events”. Arch Intern Med. 2012.
Kaeberich A, Reindl I, Raaz U, et al. Comparison of unfractionated heparin, low-molecular-weight heparin, low-dose and high-dose rivaroxaban in preventing thrombus formation on mechanical heart valves: results of an in vitro study. J Thromb Thrombolysis. 2011;32(4):417-25. [pmid: 21773837].
Lip GY, Lane DA. Does warfarin for stroke thromboprophylaxis protect against MI in atrial fibrillation patients?. Am J Med. 2010;123(9):785-9. [pmid: 20655037].
Loke YK, Kwok CS. Dabigatran and rivaroxaban for prevention of venous thromboembolism--systematic review and adjusted indirect comparison. J Clin Pharm Ther. 2011;36(1):111-24. [pmid: 21198726].
McKellar SH, Abel S, Camp CL, et al. Effectiveness of dabigatran etexilate for thromboprophylaxis of mechanical heart valves. J Thorac Cardiovasc Surg. 2011;141(6):1410-6. [pmid: 21429525].
Poultsides LA, Gonzalez Della Valle A, Memtsoudis SG, et al. Meta-analysis of cause of death following total joint replacement using different thromboprophylaxis regimens. J Bone Joint Surg Br. 2012;94(1):113-21. [pmid: 22219258].
Roskell NS, Lip GY, Noack H, et al. Treatments for stroke prevention in atrial fibrillation: a network meta-analysis and indirect comparisons versus dabigatran etexilate. Thromb Haemost. 2010;104(6):1106-15. [pmid: 20967400].
Tzeis S, Andrikopoulos G. Novel Anticoagulants for Atrial Fibrillation: A Critical Appraisal. Angiology. 2011.
Watanabe M, Siddiqui FM, Qureshi AI. Incidence and management of ischemic stroke and intracerebral hemorrhage in patients on dabigatran etexilate treatment. Neurocrit Care. 2012;16(1):203-9. [pmid: 21748501].