# STUDY SELECTION FORM

## Criteria for Inclusion and Exclusion of RCTs

### Inclusion criteria

- An RCT or a secondary data analysis from an RCT comparing a newer anticoagulant to an eligible comparator (warfarin and LMWH are the two comparators we are accepting for the various key questions)
- Sample population with history of chronic nonvalvular AF, deep venous thromboembolism, or mechanical valve replacement. Atrial fibrillation may be assessed by any accepted threshold on any valid diagnostic tool (e.g., electrocardiogram and/or echocardiogram).
- Sample population ≥ 18 years of age
- Outpatient setting (community clinic, medical clinic or office, or transitioning from inpatient for acute treatment to long-term outpatient management)
- Random allocation to the intervention groups
- Reports at least one of the included outcomes:
  ○ KQs 1–3: The main outcome is a thromboembolic event. Thromboembolic events must be documented radiologically and produce clinical symptoms. Asymptomatic thromboembolism (e.g., detected on surveillance imaging) will not be included.
  ○ KQs 1–3: Other outcomes are mortality, health-related quality of life, and patient treatment experience—the latter two measured by a validated instrument.
  ○ KQ 4: Adverse effects will be specific to the interventions examined and will include bleeding complications, myocardial infarction, and gastrointestinal adverse effects.
- Study duration of at least 6 months (KQ 2 acute treatment) or at least 12 months (KQ 1, KQ 2 chronic treatment, KQ 3, KQ 4)
- Peer-reviewed publication

### Exclusion criteria

- Non-English language publication
- Cross-sectional studies
- Pregnant population
- Studies with sample size <50
- Studies with <6 months postrandomization outcomes

## Eligibility Criteria for Observational Studies

- Patients: chronic atrial fibrillation or VTE treated with an oral DTI or FXa inhibitor
- Comparator: none or adjusted-dose warfarin
- Outcomes: adverse events
- Timing: ≥ 3 months use
- Setting: any outpatient
- Study designs:
  ○ Comparative: secondary analyses from RCTs (including patient level meta-analysis), cohort studies (prospective or retrospective-including analyses of claims databases), case control, cross-sectional.
  ○ Noncomparative: case-reports, case-series.