# SEARCH STRATEGIES

Table A-1 Search strategy for RCTs (PubMed, February 2012)

Step | Category | Terms | Result
1 | Newer anticoagulants | dabigatran OR desirudin OR ximelagatran OR edoxaban OR rivaroxaban OR apixaban OR betrixaban OR YM150 OR razaxaban OR “factor Xa inhibitors” OR “factor Xa inhibitor” OR “fxa inhibitors” OR “fxa inhibitor” OR “direct thrombin inhibitor” OR “direct thrombin inhibitors” OR DTIs OR “novel anticoagulants” OR “new anticoagulants” OR “novel anticoagulant” OR “new anticoagulant” OR “newer anticoagulants” OR “newer anticoagulant” AND | 3289
2 | Disorders of interest | “Venous Thrombosis”[Mesh:noexp] OR “Venous Thromboembolism”[Mesh] OR “Pulmonary Embolism”[Mesh] OR “Atrial Fibrillation”[Mesh] OR “Heart Valve Prosthesis”[Mesh] OR “Aortic Valve”[Mesh] OR “Mitral Valve”[Mesh] OR deep vein thrombosis OR AF OR dvt OR PE OR pulmonary embolism OR mechanical heart valve OR mechanical heart valves OR “mechanical valve” OR “mechanical valves” OR “mechanical mitral” OR “mechanical aortic” OR thromboembolism AND | 217463
3 | Study designs | randomized controlled trial[Publication Type] OR random* | 711597
4 | Combine results and apply limits | #1 AND #2 AND #3 English, Publication Date from 2001 to 2011 | 320

Table A-2 Search strategy for observational studies (February 2012)

Step | Category | Terms | Results
1 | Newer anticoagulants | Dabigatran[tiab] OR desirudin[tiab] OR edoxaban[tiab] OR rivaroxaban[tiab] OR apixaban[tiab] OR betrixaban[tiab] OR YM150[tiab] OR razaxaban[tiab] OR “dabigatran etexilate”[Supplementary Concept] OR “desirudin”[Supplementary Concept] OR “edoxaban”[Supplementary Concept] OR “rivaroxaban”[Supplementary Concept] OR “apixaban”[Supplementary Concept] OR “betrixaban”[Supplementary Concept] OR “razaxaban hydrochloride”[Supplementary Concept] OR “factor Xa, Glu-Gly-Arg-”[Supplementary Concept] OR “KFA1411”[Supplementary Concept] AND | 1112
2 | Disorders of interest | “Venous Thrombosis”[Mesh:noexp] OR “Venous Thromboembolism”[Mesh] OR “Pulmonary Embolism”[Mesh] OR “Atrial Fibrillation”[Mesh] OR “Heart Valve Prosthesis”[Mesh] OR “Aortic Valve”[Mesh] OR “Mitral Valve”[Mesh] OR “deep vein thrombosis”[tiab] OR “atrial fibrillation”[tiab] OR dvt[tiab] OR “pulmonary embolism”[tiab] OR “mechanical heart valve”[tiab] OR “mechanical heart valves”[tiab] OR “mechanical valve”[tiab] OR “mechanical valves”[tiab] OR “mechanical aortic”[tiab] OR thromboembolism[tiab] AND | 145374
3 | Study designs | (“evaluation studies”[Publication Type] OR “evaluation studies as topic”[MeSH Terms] OR “evaluation study”[tiab] OR evaluation studies[tiab] OR “intervention studies”[MeSH Terms] OR “intervention study”[tiab] OR “intervention studies”[tiab] OR “case-control studies”[MeSH Terms] OR “case-control”[tiab] OR “cohort studies”[MeSH Terms] OR cohort[tiab] OR “longitudinal studies”[MeSH Terms] OR “longitudinal”[tiab] OR longitudinally[tiab] OR “prospective”[tiab] OR prospectively[tiab] OR “retrospective studies”[MeSH Terms] OR “retrospective”[tiab] OR “follow up”[tiab] OR “comparative study”[Publication Type] OR “comparative study”[tiab] OR “Case Reports”[Publication Type] OR “case report”[tiab] OR “case series”[tiab] OR observational[tiab]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Comment[ptyp]) | 4927238
3 | Combine results and apply limits | #1 AND #2 AND #3 Publication Date from 2001 to 2012 | 278
4 | Additional study designs | “Case Reports”[Publication Type] OR “Case-Control Studies”[Mesh]) OR “Cohort Studies”[Mesh] OR “case report”[tiab] OR cohort[tiab] OR case- control[tiab] OR “case series”[tiab] | 2841521
5 | Combine results and apply limits | #1 AND #2 AND #4 Publication Date from 2001 to 2012 | 47

Table A-3 Search strategy for systematic reviews (PubMed, February 2012)

Step | Category | Terms | Results
1 | New oral anticoagulants | Dabigatran[tiab] OR desirudin[tiab] OR edoxaban[tiab] OR rivaroxaban[tiab] OR apixaban[tiab] OR betrixaban[tiab] OR YM150[tiab] OR razaxaban[tiab] OR “dabigatran etexilate”[Supplementary Concept] OR “desirudin”[Supplementary Concept] OR “edoxaban”[Supplementary Concept] OR “rivaroxaban”[Supplementary Concept] OR “apixaban”[Supplementary Concept] OR “betrixaban”[Supplementary Concept] OR “razaxaban hydrochloride”[Supplementary Concept] OR “factor Xa, Glu-Gly-Arg-”[Supplementary Concept] OR “KFA1411”[Supplementary Concept] | 1121
2 | Disorders of interest | “Venous Thrombosis”[Mesh:noexp] OR “Venous Thromboembolism”[Mesh] OR “Pulmonary Embolism”[Mesh] OR “Atrial Fibrillation”[Mesh] OR “Heart Valve Prosthesis”[Mesh] OR “Aortic Valve”[Mesh] OR “Mitral Valve”[Mesh] OR “deep vein thrombosis”[tiab] OR “atrial fibrillation”[tiab] OR dvt[tiab] OR “pulmonary embolism”[tiab] OR “mechanical heart valve”[tiab] OR “mechanical heart valves”[tiab] OR “mechanical valve”[tiab] OR “mechanical valves”[tiab] OR “mechanical aortic”[tiab] OR thromboembolism[tiab] | 145502
3 | Study designs | Systematic[sb] | 170174
3 | Combine results and apply limits | Search #1 AND #2 AND #3 Publication Date from 2001 to 2012 | 64