# SUMMARY AND DISCUSSION

## SUMMARY OF EVIDENCE BY KEY QUESTION

### Key Question 1

Twelve studies meeting inclusion criteria provided data relevant to Key Question 1.^8,9,17-27^ These studies addressed a variety of objectively assessed and self-reported visual dysfunctions including accommodation dysfunction and refractive errors; convergence insufficiency or dysfunction; diplopia; dry eye; nystagmus or fixation dysfunction; photosensitivity, photophobia, or light sensitivity; pursuit or saccadic dysfunction; strabismus and cranial nerve palsy; visual field defect; and other types of visual impairment or dysfunction.

Evidence from a large study by Dougherty and colleagues19 suggests that visual dysfunction is not commonly diagnosed in U.S. Service Members who experienced a TBI but who do not have an ocular injury or prior history of visual or ocular dysfunction. However, prevalence estimates of visual dysfunction varied greatly across the studies included in this review. The differences in frequencies reported across studies are likely due to differences in study populations and settings. Specifically, studies included different proportions of participants with mild versus moderate/severe TBI history, inpatient and outpatient settings, and settings treating only patients with current symptoms.

The study by Dougherty and colleagues19 provides strong evidence about the prevalence of visual dysfunction diagnosed in Veterans who have TBI documented in their VA medical records. However, there are likely many other Veterans who may have experienced one or more TBIs or blast exposures but do not have this coded in their medical record for a variety of reasons (eg, not reporting TBIs or blast exposure while in combat, not being aware that blast exposure or hit to the head is severe enough to warrant a TBI diagnosis, etc). While large administrative datasets can provide valuable information about entire populations of Veterans served by the VA, these data need to be interpreted with caution because of the lack of granularity and manner in which the data is collected and compiled. For example, in the Dougherty study, it is unclear what type of provider diagnosed visual dysfunction, and what types of assessments were conducted. This study relied on ICD-9 data likely gathered from routine eye care appointments; data gathered in non-screening contexts are expected to provide lower prevalence estimates than data gathered during comprehensive screening assessments for a broad range of visual dysfunction.

Many of the included studies were conducted at PRCs or PNSs, in particular, at Palo Alto VA clinics. We contacted some of the authors in an attempt to ensure that data on the same patients were not reported in more than one study, though it is possible that there may be some overlap in study populations across some of the included studies. Because of the productivity of the researchers at these facilities, it is likely that this review provides a relatively thorough summary of data for these specific clinical populations, and additional research in other settings is likely needed to provide a more general, comprehensive picture of visual dysfunction in U.S. Service Members and Veterans across clinical settings.

Though this review was not designed to determine whether visual dysfunction is more common in individuals with TBI history compared to those without, similar inconsistency in results across settings was found in studies comparing visual dysfunction frequency in individuals with TBI history versus control participants without TBI history. Overall, while visual dysfunction may be commonly reported by or diagnosed in some groups with TBI history (eg, PRC inpatients screened using comprehensive visual examination, many with comorbid ocular injuries9,21), visual dysfunction is infrequently diagnosed in other groups with TBI history (eg, unscreened samples of U.S. Service members without ocular injuries or prior history of visual dysfunction19).

### Key Question 2

Only 4 studies meeting inclusion criteria provided evidence for Key Question 2.^16,18,27,28^ These studies reported outcomes similar to those found for Key Question 1. In aggregate, all studies included in this review can provide policymakers and clinicians with a rough estimate of the types of visual dysfunctions that some individuals with TBI history may present with in eye care clinic settings, though the findings are limited by the small body of included literature.

### Study Characteristics and Quality

Study quality was assessed pertaining to the Key Questions for all included studies. Though we excluded studies selecting patients based on visual dysfunction for Key Question 1, some methods such as outcome assessment were unclearly reported in some studies (see Tables 3-13), resulting in the potential for biased results. Additionally, none of the included studies stratified results by TBI severity. The best estimates of frequency of clinically significant, diagnosed visual dysfunction come from a study by Dougherty and colleagues which excluded patients with ocular injuries or visual disorders prior to the TBI.19 This study did not screen patients to determine prevalence, instead reporting U.S. Service Member diagnostic results from a large-scale administrative military healthcare database. Eight studies reporting prevalence estimates included only those patients with TBI history who had current symptoms and were being treated at VA PRCs and PNSs; not surprisingly, frequencies of visual dysfunction were significantly higher in these studies.

### Publication Bias

Given that the body of evidence relevant to this review was based on observational studies, and none of the studies reported registered protocols or a priori established primary aims or analyses, we were not able to formally assess publication bias.

### Heterogeneity

Included studies addressed a variety of visual outcomes assessed by different methods in unique populations. Therefore, we were unable to combine studies quantitatively. Instead we provided a summary of findings for each key question and group of outcomes, with tabular presentations of study-level results. We provided a synthesis of the data for certain outcomes assessed across multiple studies, though results were often inconsistent across these studies, likely due to heterogeneity of study populations and assessment methods.

### Applicability of Findings to the VA Population

The findings from this body of evidence are very applicable to the VA population, as the majority of the included studies were conducted in VA or U.S. military healthcare settings. Prevalence estimates of a broad group of unscreened U.S. Service Members suggest that clinically significant, diagnosed visual dysfunction is uncommon in this general population,19 though this study by Dougherty and colleagues relied on data from 2004 through 2007; it is likely that as the OEF/OIF/OND conflicts progressed, clinicians and Veterans became more aware of both TBI and potential associations with visual dysfunctions. Therefore, an examination of more recent data on these populations and outcomes is likely warranted to ensure comprehensiveness and generalizability of the results. Results from studies of patients screened for visual problems at VA PNSs or PRCs suggest that visual dysfunction is quite common for this group of Veterans who often have histories of severe injuries and multiple comorbid conditions.

## FUTURE RESEARCH NEEDS

Well-designed, large-scale, prospective cohort studies on populations of interest provide the most accurate prevalence estimates and information about the relative frequency of symptoms. Ideally, longitudinal data on a large group of U.S. Service Members could be collected prior to TBI exposure. Screening the entire group for visual dysfunction after a portion had experienced a TBI could provide precise estimates of relative risk and prevalence when TBI history, ocular injuries, and time since injury are accounted for. Additionally, potential moderating variables such as comorbid PTSD or blast versus other mechanism of injury should be examined since studies included in this review provide preliminary evidence of associations among these variables and some types of visual dysfunction. Longitudinal studies could also better answer remaining questions related to prognosis over time than many of the cross-sectional studies included in this report. Research on effective treatments for visual problems experienced by individuals with TBI history was outside the scope of this review, though this information could help guide VA treatment options for affected Veterans, and additional research may be needed to establish referral guidelines for visual symptom complaints for Veterans with TBI history.

## CONCLUSIONS

Studies included in this systematic review report a range of frequencies of visual dysfunction in people with TBI history. The wide ranges of frequencies for visual dysfunction outcomes reported in the included studies are likely due to population and setting heterogeneity across studies. While some studies reported results from individuals regardless of current symptoms, many of the included studies were conducted in VA PRCs and PNSs, clinics that only serve Veterans with current symptoms associated with TBI history as well as other, often serious, comorbidities. Overall, findings suggest that visual dysfunction in a general population of U.S. Service Members with TBI history who are treated in military healthcare systems is diagnosed with a frequency of 7.3% for disorders of accommodation and refractive errors and a frequency of less than 1% for other visual dysfunctions. Conversely, other studies of Veterans with TBI history and current symptoms being treated in inpatient and outpatient TBI rehabilitation clinics report higher frequencies, often over 50% for some types of visual dysfunction such as accommodation and refraction disorders, convergence insufficiency or dysfunction, dry eye syndrome, photosensitivity, pursuit or saccadic dysfunction, and self-reported visual impairments.