# RESULTS

## LITERATURE FLOW

We reviewed 1299 titles and abstracts from the electronic search. After applying inclusion/exclusion criteria at the abstract level, 118 full-text articles were reviewed, as shown in Figure 1. Of the full-text articles, we excluded 103 that did not meet inclusion criteria. We grouped the studies by outcome and Key Question. Figure 1 details the exclusion criteria and the number of references related to each of the Key Questions. We identified 12 primary studies (13 references) that addressed Key Question 1, and 4 primary studies that addressed Key Question 2; 2 studies provided information addressing both Key Questions for a total of 13 included primary studies published in 15 papers.8,9,16-27 Two studies reported results for U.S. or Canadian civilians16,22; the rest reported results for U.S. Veterans or active-duty Service Members of the U.S. military. Table 2 shows the characteristics of the primary studies, and the following sections detail findings according to Key Questions, outcomes, and moderators.

Figure 1 Literature Flow Chart

Table 2 Sample and Study Characteristics

Citation and KQ | Study design; TBI Comparison group | TBI, control sample size | TBI severity; definition | Mechanism of injury; time since injury | Ocular injuries | Age in years, M (SD) | Gender; Race/Ethnicity | Sample characteristics and selection
Alvarez, 2012^16^ KQ2 | Case series; None | 557 | NR | MVCs (70.9%), falls (14.7%), a strike or blow to the head (9.2%), sports injury (2.5%), other (2.7%; gunshot, assaults, or unspecified) Time NR | NR | 40.3 (SD 17.4, range 5-89) | 338/557 (61%) male | Inpatients with vision symptoms referred from Kesser Institute of Rehabilitation, John F. Kennedy Medical Center, and Robert Wood Johnson University Hospital in New Jersey. Outpatients: New Jersey private practice. January 1989 to February 2003; Sample is approximately one half of all neurologically impaired patients referred by neurologists.
Brahm, 2009^17^ KQ1 | Cross-sectional; None | 192 | Mild, moderate, and severe. Inpatients: No definition; Outpatients: Mild TBI screening using expanded version of 3-item DVBIC tool | 57/68 (84%) blast, 11/68 (16%) non-blast in the PRC- group. Time NR | 26/68 (38.2%) had “ocular injuries” | 28.6 (median = 26.0) for PRC inpatients. | 65/68 (96%) male | Palo Alto PRC inpatients: 68 consecutive patients; December 2004 to April 2008 Palo Alto PNS outpatients: 124 consecutive patients; August 2006 to December 2007
Bulson, 2012^18^ KQ1 & KQ2 | Case series and cross-sectional data; None | 100 (KQ 1) 33 (KQ 2) | NR; TBI diagnosis given at initial post-deployment evaluation by a medical doctor. | Multiple blast injuries (69%), blasts associated with MVCs (13%), single blasts (10%), falls (7%), isolated MVCs (1%) Time NR | NR | 29.9 (range 21-55) | 99% male | Portland VA Medical Center Post-deployment Clinic: 185 OEF/OIF Veterans; January 2009 to 2012
Cockerham, 2013^8^ KQ1 | Case control; Recruited 18 men similar age range, ethnicity, but without TBI | 53, 18 | 32% = mild, 49% = moderate, 19% = severe; definition NR | 44/53 (83%) blast, 6/53 (11%) MVC, 3/53 (6%) fall Time ranged from 1-60 months (median = 6 months). | Eyes with open-globe injury and those using topical ocular medications were excluded | 26 (range 19-46) | 100% male 34/53 (65%) White, 19/53 (35%) non-White. | VA Palo Alto PRC inpatients; began testing tear production in 2006 in inpatients and former inpatients returning for eye examinations. No report of consecutive patient selection.
Dougherty, 2011^19^ KQ1 | Retrospect-ive cohort; same patient group with non-TBI blast injury | 837, 1417 | NR; rating system used was 0 = no TBI, 1 = minor, 2 = moderate, 3-5 = serious to critical according to ICD-9-CM (Thurman et al 1995) and AIS (Gennarelli et al 2005) | All TBI and control participants were injured by blast exposure Time NR, based on data collected during deployment in the combat zone | “Those who sustained eye injury were excluded from this analysis” | TBI: Median = 22 (range 18-59) Control: Median = 23 (range 18-59) | 99.4% male Control = 98.7% male | Expeditionary Medical Encounter Database; March, 2004 to February, 2007: Medical records completed “in the combat zone, nearest to the point of injury” merged with DOD records. All had blast exposure. “US Service members who met the following criteria were included” suggesting all eligible participants included. Inclusion criteria stated “having only one recorded injury event and having not received a diagnosis of ocular or visual disorder prior to the injury event.”
Goodrich, 2013^9^ Goodrich, 2013^21^ KQ1 | Cross-sectional; None | 100 | 27/98 Mild; 71/98 Moderate-Severe; Severity obtained from a DVBIC evaluation record, physician entry, and ACRM criteria applied to chart review | 50/100 blast, all in Afghanistan or Iraq. 50/100 non-blast: MVC (58%); fall (16%); assault (12%); pedestrian struck by vehicle, gunshot, bicycle injury (4% each); snowboard injury (2%). Most occurred in the U.S. M = 8 months (range 2-56 wks) PTSD: M = 15.3 months No PTSD: M = 2.9 months Blast: M = 1.01 yrs (SD = 1.18) No Blast: M = .32 yrs (SD = .52) | 29/98 “eye/orbit trauma” Non-blast: 29% Blast: 31% | PTSD: M = 32.8 (range 19-59) No PTSD: M = 26.37 (range 19-63) No Blast: 29 (range, 19 to 63); Blast: 29 (range, 19 to 55) | 95% Male Non-blast: 48/50 (96%) male. Blast: 47/50 (94%) male. | Palo Alto PRC inpatients with documented eye examinations with optometry. 16/50 blast TBI patients exposed to more than one blast; 4/50 non-blast TBI patients had past head injuries. No report of consecutive patient selection.
Goodrich, 2007^20^ KQ1 | Cross-sectional; None | 50 | NR | Blast = 50%; MVCs = 26%; Assault = 8%; Falls = 8%; Gunshot and/or shrapnel wounds = 4%; Anoxia = 4%. Combat = 59%. Time NR | 17 (34.0%) “eye or orbit damage” | M = 28.1 (median 26, range 19-56) | 45/50 (90%) male | Palo Alto PRC: Comprehensive vision examinations of OEF/OIF inpatients injured during combat or deployment from December 2004 to November 2006. “A specific eye complaint was unnecessary for referral, and the clinic attempted to see all Veterans and active-duty personnel admitted to the PRC.”
Hartvigsen, 2014^22^ KQ1 | Cross-sectional; None | 1716 | 100% Mild; endorsed one or more: amnesia or loss of memory; LOC, confusion or disorientation; excluded those with LOC > 30 mins. | All MVCs Included those who made an insurance claim within 42 days of injury, followed up at 6 weeks and 3, 6, 9, and 12 months following the insurance claim | NR | M = 37.7 (16.1) | 812/1716 (47.3%) male | December, 1997 to November, 1999. All traffic injuries in persons 18 years or older who made an insurance claim in Saskatchewan, Canada.
Lemke, 2013^23^ KQ1 | Case control; Healthy controls (age M = 59, gender = 39% male); comparison data from a different study | 60 | Mild 37%, Moderate or Severe 38%, Penetrating 25%; Severity based on duration of LOC, PTA, GCS, history of penetrating head injury, imaging | Blast exposure 8.7 months (range 2-82 months) to initial testing | No open globe injury | Mean = 27 | 95% male | VHA hospital rehabilitation center; December, 2006 to January, 2012. TBI from combat blast exposure. Consecutive patients.
Lew, 2011^26^ KQ1 | Retrospect-ive cohort; Deployed non-TBI patients | 12,521 9,196 | Mild 85.4%; definition NR | Deployment-related TBI, including blast; blast exposure in 83.3% of cases, 70.4% of controls. Time NR | NR | 31.3 (8.6) | 93.9% male | Retrospective record review of 36,919 TBI evaluations performed in VHA between Oct 2007 and June 2009. 12,521 with deployment-related TBI and 9106 without TBI. Excluded patients with non-deployment TBI. Sample selection not specified, implies inclusion of all records.
Lew, 2009^25^ KQ1 | Cross-sectional; None | 62 | Mild, n=25 (40.3%) Moderate, n=12 (19.4%) Severe, n=25 (40.3%) Definition NR | Blast exposure M = 238.5 days | NR | 27.3 (7.0) | 93.5% male 74.2% Caucasian | Palo Alto PRC patients admitted Dec 2004 to March 2008 not previously admitted to the PRC for TBI treatment. Patients with blast-related TBI who completed both hearing and vision evaluations. “Retrospective chart review on all new admissions.” 79 patients with blast-related TBI had hearing and vision evaluations ordered, but only 62 completed evaluations and were included.
Lew, 2007^24^ KQ1 | Cross-sectional; None | 62 | NR; 50% reported LOC; 31% reported only alteration of consciousness | 79% blast, 8% MVC, 8% blunt trauma, 3% penetrating head injuries Time NR | NR | NR | NR | Palo Alto PNS; July 2006 to February 2007; 89% OEF/OIF Veterans, 5% Veterans from prior wars, 6% did not have combat related injuries (the latter 2 groups were retained to accurately represent the population flagged by the screening process). 71% PTSD, 55% Cognitive Disorder, 42% Both, 16% Neither. Consecutive participants.
Magone, 2014^28^ | Case series | 31 | Mild; LOC for up to 30 min or an alteration in mental state and/or memory loss for less than 24 hours | Blast-induced M = 50.5, SD = 19.8 months since injury, range 16-91 months | None | 30.5(8.3) | 94% male | All Washington DC VAMC eye clinic patients with blast induced mTBI; January 2009-December 2011.
Stelmack, 2009^27^ KQ1 & KQ2 | Case series and cross-sectional data; None | 88 | NR | NR | 6% = orbit/eye trauma | M = 31 | 92% male | Hines PNS; October 2005 to March 2008. “The majority (88%) were injured in OEF or OIF. Most (95%) presented with nonpenetrating injuries.” No report of consecutive patient selection: “A list of patients was provided by a social work care manager and the Rehabilitation Service Line Coordinator.”

Note. M = Mean; ED = Emergency Department; TBI = Traumatic Brain Injury; KQ = Key Question; NR = Not Reported; PRC = Polytrauma Rehabilitation Center; PNS = Polytrauma Network Site; MVC = Motor Vehicle Crash; DVBIC = Defense and Veterans Brain Injury Center; Abbreviated Injury Scale = AIS; DOD = Department of Defense; ACRM = American Congress of Rehabilitation Medicine; GCS = Glasgow Coma Scale; LOC = Loss of Consciousness, PTA = Posttraumatic Amnesia.

## KEY QUESTION 1 What is the prevalence or incidence of visual dysfunction in a general population of individuals who have been diagnosed with a TBI?

Twelve studies (published in 13 papers) of patients with TBI history met inclusion criteria for Key Question 1. The prevalence of visual dysfunction ranged widely according to the patient population examined, study setting, and whether or not patients underwent examination to screen for visual dysfunction. We excluded studies only providing data on patients who were referred or self-referred to the study based on visual complaints because these studies do not provide accurate data on the prevalence of visual dysfunction in unselected populations (ie, participants not selected for inclusion in the study based on visual dysfunction) with history of TBI. Sample selection criteria for each study are documented in Table 2. None of the studies meeting inclusion criteria stratified results based on TBI severity. There were 2 main types of study settings: settings that treat patients regardless of current, suspected TBI-related symptoms, and settings that treat only patients with current, suspected TBI-related symptoms.

### Summary of findings from studies of patients in settings that treat patients regardless of current symptoms

Four studies included general populations of patients with TBI history regardless of current symptoms. In these studies, participants were all patients with TBI history (1) seen at a post-deployment clinic for a general medical appointment and screened for vision-related symptoms,18 (2) with military record diagnostic data on visual dysfunctions,19 (3) presenting to a Canadian emergency department related to a motor vehicle crash and screened for post-concussive symptoms including vision-related symptoms,22 and (4) who had TBI evaluations performed at the VA and were screened for neurobehavioral symptoms including vision-related symptoms.26

One study by Dougherty and colleagues of an unscreened group of U.S. Service Members used a large administrative database to identify those with clinically diagnosed visual dysfunction.19 This study reported data on clinical diagnosis in an unscreened group of U.S. Service Members, and excluded individuals with ocular injury and diagnosis of ocular or vision disorders prior to the TBI. This study found low rates of individual types of visual problems or dysfunction (0.1% to 7.3%, see Table 1), and reported that, overall, 11% of patients were diagnosed with one or more types of visual dysfunction. Unlike studies in which all participants are screened, this study provides an assessment of clinically significant impairment because patients experienced visual dysfunction to a degree that resulted in clinical presentation and diagnosis.

Table 1 Summary of Findings: Ranges of Visual Dysfunction Frequencies Across Studies

| Studies including patients with TBI history [underlined: regardless] of current symptoms | | Studies including patients with TBI history who [underlined: all] have current symptoms
Outcome | Unscreened | Screened | Screened
Accommodation Dysfunction and Refractive Errors | 7.3% (1 study19) | 3.0% (1 study18) | 19.0 - 66.7% (6 studies9,17,20,21,24,27,28)
Convergence Insufficiency or Dysfunction | No studies | No studies | 11.0 - 62.5% (6 studies9,17,20,21,24,27,28)
Diplopia | No studies | No studies | 3.0 - 40.0% (4 studies9,20,21,27,28)
Dry Eye | 0.1% (1 study19) | 2.0% (1 study18) | 93.0% with one or more positive tests (1 study8)
Nystagmus or Fixation Dysfunction | No studies | No studies | 0.0 - 23.4% (5 studies9,17,20,21,24,27)
Photosensitivity, Photophobia, or Light Sensitivity | No studies | 5.0 – 54.0% (1 study, diagnosed vs self-report18) | 51.0 - 59.0% (3 studies, all self-report9,21,24,28)
Pursuit or Saccadic Dysfunction | No studies | No studies | 2.0 - 70.8% (5 studies9,17,21,24,27)
Strabismus and Cranial Nerve Palsy | 0.6% (1 study19) | | 0.0 - 37.5% (4 studies9,17,21,24,27)
Visual Field Defect | 0.1% (1 study19) | 2.0% (1 study18) | 0.0% - 38.8% (3 studies17,20,27)
Visual Impairment or Dysfunction, Diagnosed | 0.4% (1 study19) | 22.0% (1 study18) | 8.5% (1 study17)
Visual Impairment or Dysfunction, Self-Reported | No studies | 8.8 - 47.0% (3 studies18,22,26) | 32.2 - 77.4% (6 studies9,17,21,23,25,27,28)

The other 3 studies used self-report measures to screen participants18,22,26 and found higher rates of visual dysfunction (8.8% to 54%, see Table 1) than the data from Dougherty and colleagues that reported on unscreened patients with diagnosed visual dysfunction. One of these screening studies18 also referred patients who self-reported visual problems for eye examinations, and the resulting visual diagnoses were less frequent upon examination compared to self-report (2% to 22%, see Table 1).

### Summary of findings from studies of only patients with current symptoms

The second main type of study population examined in this review came from studies conducted in Polytrauma Rehabilitation Centers (PRCs) and Polytrauma Network Sites (PNSs) within the VA.8,9,17,20,21,23-25,27 Both types of treatment facilities provide interdisciplinary, rehabilitation care to Veterans who experienced TBI or polytrauma, but serve populations with different care needs. The 5 PRCs provide acute, inpatient care to those with more complex and severe TBI or polytrauma. The 23 PNSs provide care to those who are discharged from PRCs and need continued rehabilitation services, as well as to Veterans who require less intensive care for their TBI or polytrauma. In 2008, the VA began requiring all PRC patients with a history of TBI to “have a TBI-specific ocular health and visual functioning examination performed by an optometrist or ophthalmologist.”11 While Veterans treated at PRCs and PNSs differ in symptom severity and complexity, their results are grouped in this report because data from PRCs and PNSs were commonly aggregated in the included studies. However, results tables for each type of visual dysfunction stratify findings according to inpatient versus outpatient status, when these data were available in the original studies.

Because PRC and PNS patients receive care based on current symptoms, some of which may be vision-related, and because the patients undergo eye exams designed to screen for many types of visual problems, it is not surprising that the rates of visual dysfunction in these patient populations were generally much higher (0 to 93%, see Table 1) than in general VA populations.

A summary of the range of frequencies for each type of visual dysfunction included in this report is illustrated in Table 1, with results separated to reflect different study populations.

### Methodological considerations

In addition to participant populations and selection factors, another factor that can influence prevalence estimates relates to outcome assessment.14 The included studies used a variety of assessment methods to evaluate different types of visual dysfunction. These outcomes and assessment methods are reported in the results tables for each type of visual dysfunction. Studies based on administrative databases likely underestimate prevalence of outcomes as populations are not screened and diagnostic outcome data may be inconsistently entered.19,22,26 In contrast, studies using clinic-based outcome assessments may be biased if providers or patients are aware of study hypotheses, particularly if outcomes require subjective assessment (ie, there is the potential for outcome ascertainment bias). None of the studies that employed clinic-based outcome assessment methods described outcome validation methods such as dual or blinded assessment, and therefore the potential for biased results from these studies is unclear.8,9,17,18,20,21,23-25,27

Key Questions in this systematic review do not focus on assessing causality or determining if visual dysfunction is more common in individuals with TBI history compared to those without. Though some included studies report data on control groups without TBI history, we did not assess study quality related to causal associations between TBI history and visual dysfunction.

### Summary of Findings

The following sections describe the findings from studies addressing Key Question 1 in this review. The sections are presented alphabetically according to visual dysfunction outcome, and include prevalence estimates from included studies as well as comparison data, when available.

### Accommodation Dysfunction and Refractive Errors Findings

Seven studies described in 8 publications reported data on accommodation and refraction dysfunction in individuals with a history of TBI. These results are summarized in Table 3. Frequency of accommodation dysfunction and refractive errors varied greatly across the 6 studies reporting estimates not stratified by potentially confounding factors, ranging from under 10 percent in 2 studies,18,19 around 20 percent in 3 studies,20,24,27 to 66.7% in one study.9,21 Only one study included a control group: Dougherty and colleagues report a 7.3% frequency of disorders of accommodation and refraction for those with TBI history compared to 5.8% for a similar population of control participants who were also deployed and blast-exposed, but who did not experience a TBI.19

Table 3 Accommodation Dysfunction and Refractive Errors in Individuals with TBI History

Citation | Outcome measure | Prevalence estimates (stratified if available) | P value
Brahm, 2009^17^ | Pull-away method used for patients under age 40 | Inpatient: 21/53 (39.6%) Outpatient: 47/99 (47.5%) Blast, inpatient: 19/45 (42.2%) No Blast, inpatient: 2/8 (25.0%) Blast, outpatient: 42/92 (45.7%) No Blast, outpatient: 5/7 (71.4%) | NR
Bulson, 2012^18^ | Diagnosed accommodative dysfunction during eye clinic evaluation | 3/100 (3%) | NR
Dougherty, 2011^19^ | ICD-9-CM code 367 “Disorders of accommodation and refraction” | 61/837 (7.3%) No TBI Control: 82/1417 (5.8%) | NR
Goodrich, 2013^9^ Goodrich, 2013^21^ | Accommodative amplitude tested monocularly on patients 40 years of age and younger with pull-away technique, rated as normal or deficient using age-established norms. | 50/75 (66.7%) PTSD: 18/27 (66.7%) No PTSD: 32/48 (66.7%) Blast: 27/39 (69.2%) No Blast: 23/36 (63.9%) | PTSD vs no PTSD: p = “non-significant” Blast vs No Blast: p = “non-significant”
Goodrich, 2007^20^ | Push-up/pull-away technique | 10/46 (21.7%) Blast: 5/21 (23.8%) No Blast: 5/25 (20.0%) | NR
Lew, 2007^24^ | NR; assessed at comprehensive eye exam. | 13/62 (21%) | NR
Stelmack, 2009^27^ | NR | 17/88 (19%) | NR

Note. TBI = Traumatic Brain Injury; NR = Not Reported; PTSD = Post-traumatic Stress Disorder. No effect sizes were reported.

Three studies reported frequency of accommodation dysfunction and refractive errors in those with TBI history stratified by subgroups. Brahm and colleagues reported a frequency of 39.6% for inpatients compared to 47.5% of outpatients.17 The authors report higher frequencies for blast-exposed inpatients than non-blast exposed inpatients, but lower frequencies for blast-exposed outpatients compared to non-blast exposed outpatients. Goodrich and colleagues report similar rates of accommodation dysfunction and refractive errors for blast- and non-blast exposed inpatients (69.2% and 63.9%, respectively).9 In a later paper on the same sample of inpatient Veterans treated in a PRC, Goodrich and colleagues report identical rates of accommodation dysfunction and refractive errors for both Veterans with TBI history with and without comorbid PTSD (66.7% in both groups).21

### Convergence Insufficiency or Dysfunction Findings

Data on convergence insufficiency or dysfunction in individuals with a history of TBI were reported in 5 studies (described in 6 publications). These results are summarized in Table 4. Frequency of convergence insufficiency or dysfunction varied greatly across the 4 studies reporting estimates not stratified by potentially confounding factors, ranging from 11% in one study27 to 62.5% in another.9,21 The other 2 studies reported frequencies of 30.4% and 46%.20,24 No studies with control groups reported data on convergence insufficiency or dysfunction.

Table 4 Convergence Insufficiency or Dysfunction in Individuals with TBI History

Citation | Outcome measure | Prevalence estimates (stratified if available) | P value
Brahm, 2009^17^ | Near Point of Convergence, > 7 cm | Inpatient: 26/61 (42.6%) Outpatient: 59/122 (48.4%) Blast, inpatient: 22/52 (42.3%) No Blast, inpatient: 4/9 (44.9%) Blast, outpatient: 52/111 (46.8%) No Blast, outpatient: 7/11 (63.6%) | NR
Goodrich, 2013^9^ Goodrich, 2013^21^ | Near Point of Convergence measured by the patient fixating on a single 20/50 letter, > 8 cm | 30/48 (62.5%) PTSD: 17/24 (70.8%) No PTSD: 13/24 (54.2%) Blast: 18/23 (78.3%) No Blast: 12/25 (48.0%) | PTSD vs no PTSD: p = “non-significant” Blast vs No Blast: p = .062
Goodrich, 2007^20^ | Near point of convergence was measured with a confrontation near target. | 14/46 (30.4%) Blast: 5/21 (23.8%) No Blast: 9/25 (36.0%) | NR
Lew, 2007^24^ | NR; assessed at comprehensive eye exam. | 28/62 (46%) | NR
Stelmack, 2009^27^ | NR | 10/88 (11%) | NR

Note. TBI = Traumatic Brain Injury; NR = Not Reported; PTSD = Post-traumatic Stress Disorder. No effect sizes were reported.

Three studies report frequency of convergence insufficiency or dysfunction in those with TBI history stratified by subgroups. Brahm and colleagues report similar frequencies for inpatients and outpatients (42.6% and 48.4%, respectively).17 The authors also report similar frequencies for blast-and non-blast exposed Veterans with the exception of a slightly higher rate for the outpatient, non-blast exposed subgroup (63.6%). Goodrich and colleagues report rates of convergence insufficiency or dysfunction for blast- and non-blast exposed Veterans of 78.3% and 48.0%, respectively, in a sample of PRC inpatients;20 however, in a different sample of PRC inpatients, they report rates of 23.8% and 36.0% for blast- and non-blast exposed Veterans.9,21 Goodrich and colleagues also report rates for those with and without comorbid PTSD (70.8% and 54.2%, respectively).9,21

### Diplopia

Diplopia in individuals with a history of TBI was reported in 3 studies (described in 4 publications). These results are summarized in Table 5. Diplopia was infrequent in 2 studies (3% and 6.5%),20,27 though significantly more common in another (40%).9,21 No studies with control groups reported diplopia outcomes.

Table 5 Diplopia in Individuals with TBI History

Citation | Outcome measure | Prevalence estimates (stratified if available) | P value
Goodrich, 2013^9^ Goodrich, 2013^21^ | NR | 36/90 (40%) PTSD: 17/38 (44.7%) No PTSD: 19/52 (36.5%) Blast: 16/43 (37.2%) No Blast: 20/47 (42.6%) | Blast vs No Blast: p = .670
Goodrich, 2007^20^ | Binocular vision function was assessed with cover tests in primary gaze at distance and near. | Total: 3/46 (6.5%) Blast: 0/21 (0.0%) No Blast: 3/25 (12.0%) | NR
Stelmack, 2009^27^ | NR | 3/88 (3%) | NR

Note. TBI = Traumatic Brain Injury; NR = Not Reported; PTSD = Post-traumatic Stress Disorder. No effect sizes were reported.

Two studies report frequency of diplopia in those with TBI history stratified by subgroups. One study reports rates of diplopia for blast- and non-blast exposed inpatients of 37.2% and 42.6% in a sample of PRC inpatients,9 while another study reports rates of 0% and 12.0% for blast- and non-blast exposed Veterans.20 One study reports rates for those with and without comorbid PTSD (44.7% and 36.5%, respectively).21

### Dry Eye

Three studies reported data on dry eye in individuals with a history of TBI. These results are summarized in Table 6. Frequency of dry eye varied greatly across the 3 studies reporting estimates not stratified by potentially confounding factors, ranging from .1% to 2% in 2 studies18,19 to 93% of Veterans obtaining at least one positive measure of dry eye in one study.8 The study by Cockerham and colleagues reported significant differences between those with TBI history compared to a control group in terms of more than one positive test of dry eye or ocular strain, but non-significant differences for basal tear production, tear film break-up time, and tear osmolarity; however, the control group was potentially very different from cases in terms of factors other than TBI history.8 Another study by Dougherty and colleagues reported a 0.1% frequency of dry eye for those with TBI history compared to 0.3% for a similar population of control participants who were deployed and blast-exposed, but did not experience a TBI.19

Table 6 Dry Eye in Individuals with TBI History

Citation | Outcome measure | Prevalence estimates or Mean (SD) (stratified if available) | Prevalence estimates or Mean (SD) for control group (if available) | P value | Effect size (95% CI)
Bulson, 2012^18^ | Diagnosed dry eye syndrome during eye clinic evaluation | 2/100 (2%) | NR | NR | NR
Cockerham, 2013^8^ | Basal tear production (BTP) < 4mm; tear film break-up time (TFBUT) < 10 sec.; tear osmolarity > 314 milliosmoles; ocular staining present (flourescein and lissamine green staining pattern scored on Oxford scale) | Total TBI, at least 1 positive test: 49/53 (93%) Total TBI, BTP: 19/53 (36%) Blast, BTP: 17/44 (39%) No Blast, BTP: 2/9 (22%) Total TBI, TFBUT 14/53 (28%) Blast, TFBUT: 14/44 (33%) No Blast, TFBUT: 0/9 (0%) Total TBI, Tear Osmolarity: 19/53 (58%) Blast, Tear Osmolarity: 13/44 (54%) No Blast, Tear Osmolarity: 6/9 (67%) Total TBI, Ocular Stain: 42/53 (28%) Blast, Ocular Stain: 35/44 (80%) No Blast, Ocular Stain: 7/9 (78%) | At least 1 positive test: 8/18 (44%) BTP: 3/18 (17%) TFBUT: 1/18 (6%) Tear Osmolarity: 4/18 (33%) Ocular Stain: 5/18 (28%) | At least 1 positive test: p < .001 BTP: p = .13 TFBUT: p = .06 Tear Osmolarity: p = .15 Ocular Stain: p < .001 | At least 1 positive test: chi-square = 19.56 BTP: chi-square = 2.3 TFBUT: chi-square = 3.57 Tear Osmolarity: chi-square = 2.07 Ocular Stain: chi-square = 15.91 No significant differences in results accounting for those on antidepressant medications considered risk factors for dry eye syndrome.
Cockerham, 2013^8^ | 3 Ocular Surface Disease Index (OSDI) categories: Visual complaints; Functional limitations; Sensitivity to conditions. Each of 12 questions scored 1 (mild) to 4 (severe) with total score tallied. Results reported as mean (SD) OSDI scores. | Total TBI, visual complaints: 23 (SD = 10) Blast, visual complaints: 24 (SD = 10) No Blast, visual complaints: 16 (SD = 10) Total TBI, functional limitations: 19 (SD = 28) Blast, functional limitations: 18 (SD = 28) No Blast, functional limitations: 24 (SD = 29) Total TBI, sensitivity: 17 (SD = 29) Blast, sensitivity: 19 (SD = 31) No Blast, sensitivity: 7 (SD = 17) | visual complaints: 2 (4) functional limitations: 0 (0) sensitivity: 1 (4) | visual complaints: p < .001 functional limitations: p < .001 sensitivity: p = .03 | visual complaints: Z = 3.5 functional limitations: Z = 3.6 sensitivity: Z = 2.2
Dougherty, 2011^19^ | ICD-9-CM code 375 “Disorders of lacrimal system” | 1/837 (0.1%) | 4/1417 (0.3%) | NR | NR

Note. TBI = Traumatic Brain Injury; NR = Not Reported; PTSD = Post-traumatic Stress Disorder.

One study reported frequency of dry eye in those with TBI history stratified by blast and no blast mechanism of injury subgroups.8 Different studies of dry eye yielded mixed findings among blast-exposed subgroups depending on the measures, and statistical significance of these differences was not reported in this study.

One study reported Ocular Surface Disease Index subscale scores for visual complaints, functional limitations, and sensitivity to conditions related to dry eye.8 This study reported significantly higher scores indicating greater symptoms by those with TBI compared to controls; however, as noted above, control participants were likely different from cases in regards to more than just TBI status.

### Nystagmus or Fixation Dysfunction

Data on nystagmus or fixation dysfunction in individuals with a history of TBI were reported in 5 studies (described in 6 publications). These results are summarized in Table 7. Frequency of nystagmus or fixation dysfunction ranged from 0%^27^ to 23.4%^9,21^ in 4 studies reporting results not stratified by potentially confounding factors. The other 2 studies reported frequencies of 2.2% and 5%.20,24 No studies with control groups reported outcome data on nystagmus or fixation dysfunction.

Table 7 Nystagmus or Fixation Dysfunction in Individuals with TBI History

Citation | Outcome measure | Prevalence estimates (stratified if available) | P value
Brahm, 2009^17^ | Various targets depending on patient abilities and acuity limits including penlights, colored targets, and single letters down to 1.25 M letter size. | Inpatient: 6/63 (9.5%) Outpatient: 8/124 (6.5%) Blast, inpatient: 5/54 (9.3%) Non-blast, inpatient: 1/9 (11.1%) Blast, outpatient: 8/112 (7.1%) Non-blast, outpatient: 0/12 (0.0%) | NR
Goodrich, 2013^9^ Goodrich, 2013^21^ | Fixation was assessed by having the patient fixate on a 20/50 near target and noting any unsteadiness or nystagmus | 22/94 (23.4%) PTSD: 9/38 (23.6%) No PTSD: 13/56 (23.2%) Blast: 8/46 (17.4%) No Blast: 14/48 (29.2%) | PTSD vs no PTSD: p = “non-significant” Blast vs No Blast: p = “non-significant”
Goodrich, 2007^20^ | Fixation stability on a near target was assessed for steadiness, and any nystagmus noted | Total: 1/46 (2.2%) Blast: 0/21 (0.0%) Nonblast: 1/25 (4.0%) | NR
Lew, 2007^24^ | NR; assessed at comprehensive eye exam. | 3/62 (5%) | NR
Stelmack, 2009^27^ | NR | 0/88 (0%)

Note. TBI = Traumatic Brain Injury; NR = Not Reported; PTSD = Post-traumatic Stress Disorder; M = M-unit, 1 M-unit is the ability to recognize a standard letter at a distance of 1 meter. No effect sizes were reported.

Three studies report frequency of nystagmus or fixation dysfunction in those with TBI history stratified by subgroups. Brahm and colleagues report similar frequencies for inpatients and outpatients (9.5% and 6.5%, respectively).17 The authors report similar frequencies for blast- and non-blast exposed Veterans with the exception of similarly exposed outpatient Veterans (7.1% vs 0.0%, respectively). Goodrich and colleagues report rates of nystagmus or fixation dysfunction for blast- and non-blast exposed Veterans of 0% and 4.0%, respectively, in a sample of PRC inpatients.20 In a different sample of PRC inpatients, they report rates of 17.4% and 29.2% for blast- and non-blast exposed Veterans and report rates for those with and without comorbid PTSD as 23.6% and 23.2%, respectively.9,21

### Photosensitivity, Photophobia, or Light Sensitivity

Three studies published in 4 papers reported data on photosensitivity, photophobia, or light sensitivity in individuals with a history of TBI. These results are summarized in Table 8. Frequency of photosensitivity, photophobia, or light sensitivity when assessed by patient self-report in 3 studies ranged from 51% to 59%.9,18,21,24 The study by Bulson and colleagues also reported photosensitivity diagnosed during an eye clinic exam; in this study, only 5% of patients with TBI history received such a diagnosis.18

Table 8 Photosensitivity, Photophobia, or Light Sensitivity in Individuals with TBI History

Citation | Outcome measure | Prevalence estimates (stratified if available) | P value | Effect size (95% CI)
Bulson, 2012^18^ | 22-item Neurobehavioral Symptom Inventory (NSI-22), self-report measure item assessing “light sensitivity” with score of 2 or greater | 54/100 (54%) | NR | NR
Bulson, 2012^18^ | Diagnosed photosensitivity during eye clinic evaluation | 5/100 (5%) | NR | NR
Goodrich, 2013^9^ Goodrich, 2013^21^ | Self-reported photosensitivity | 44/86 (51%) PTSD: 31/36 (86.1%) No PTSD: 13/48 (27.1%) Blast: 31/46 (67.4%) No Blast: 13/40 (77.5%) | PTSD vs no PTSD: p < .001 PTSD vs no PTSD adjusted for age, medication, TBI severity, and mechanism of injury: p = .002 Blast vs No Blast: p = .002 | PTSD vs no PTSD: chi-square = 23.08 PTSD vs no PTSD adjusted for age, medication, TBI severity, and mechanism of injury: Adjusted OR = 8.22 (95% CI 2.20-30.70)
Lew, 2007^24^ | Self-reported photosensitivity during evaluation | 36/62 (59%) | NR | NR

Note. TBI = Traumatic Brain Injury; NR = Not Reported; PTSD = Post-traumatic Stress Disorder.

One study reported frequency of photosensitivity, photophobia, or light sensitivity as 67.4% and 77.5% in those with TBI history stratified by blast versus no blast mechanism of injury subgroups respectively, a difference that was statistically significant.9,21 This same study reported rates of 86.1% for those with PTSD compared to only 27.1% for those without. This comparison was statistically significant (p < .001) and remained so after adjustment for age, medication, TBI severity, and mechanism of injury (p = .002).

### Pursuit or Saccadic Dysfunction

Data on pursuit or saccadic dysfunction in individuals with a history of TBI were reported in 5 studies (described in 6 publications). These results are summarized in Table 9. Frequency of pursuit or saccadic dysfunction ranged from 2%^27^ to 70.8% (saccadic dysfunction) and 37.4% (pursuit dysfunction)9,21 in 4 studies reporting results not stratified by potentially confounding factors. The other 2 studies reported saccadic and/or pursuit dysfunction frequencies of 19.6% and 25%.20,24 No studies with control groups reported outcome data on pursuit or saccadic dysfunction.

Table 9 Pursuit or Saccadic Dysfunction in Individuals with TBI History

Citation | Outcome measure | Prevalence estimates (stratified if available) | P value
Brahm, 2009^17^ | Various targets depending on patient abilities and acuity limits including penlights, colored targets, and single letters down to 1.25 M letter size. | Inpatient: 19/63 (30.2%) Outpatient: 29/124 (23.4%) Blast, inpatient: 18/54 (33.3%) Non-blast, inpatient: 1/9 (11.1%) Blast, outpatient: 27/112 (24.1%) Non-blast, outpatient: 2/12 (16.7%) | NR
Goodrich, 2013^9^ Goodrich, 2013^21^ | Saccades assessed by having a patient switch fixation between 2 targets located approximately 10 cm apart and 40 cm in front of midline; rated as normal or deficient following Northeastern State University College of Optometry oculomotor test criteria. Pursuits evaluated by having the patient follow a target that was moved into the cardinal positions of gaze. | Saccadic dysfunction: 68/96 (70.8%) Pursuit abnormalities: 37/99 (37.4%) PTSD, Saccadic dysfunction: 26/39 (66.7%) No PTSD, Saccadic dysfunction: 42/57 (73.6%) PTSD, Pursuit abnormalities: 14/41 (34.1%) No PTSD, Pursuit abnormalities: 23/58 (39.6%) Blast, Saccadic dysfunction: 29/50 (58.0%) No Blast, Saccadic dysfunction: 39/46 (84.8) Blast, Pursuit abnormalities: 15/50 (30.0%) No Blast, Pursuit abnormalities: 22/49 (44.9%) | PTSD vs no PTSD: p = “non-significant” Saccadic dysfunction, Blast vs No Blast: p = .006 Pursuit abnormalities: p = “non-significant”
Goodrich, 2007^20^ | Saccadic eye movements were assessed for accuracy and speed of eye movements between the targets. Pursuit eye movements were assessed for accuracy and smoothness. | Total: 9/46 (19.6%) Blast: 1/21 (4.8%) No Blast: 8/25 (32.0%) | NR
Lew, 2007^24^ | NR; assessed at comprehensive eye exam. | 15/62 (25%) | NR
Stelmack, 2009^27^ | NR | 2/88 (2%) | NR

Note. TBI = Traumatic Brain Injury; NR = Not Reported; PTSD = Post-traumatic Stress Disorder. No effect sizes were reported.

Three studies report frequency of pursuit or saccadic dysfunction in those with TBI history stratified by subgroups. Brahm and colleagues report similar frequencies for inpatients and outpatients (30.2% and 23.4%, respectively).17 When analyzed by blast versus non-blast exposure mechanism of injury, the authors report higher frequencies for those exposed to blast for both inpatients and outpatients. Goodrich and colleagues report rates of pursuit or saccadic dysfunction in the opposite direction for blast- and non-blast exposed Veterans (4.8% and 32.0%, respectively) in a sample of PRC inpatients.20

### Strabismus and Cranial Nerve Palsy

Strabismus and cranial nerve palsy in individuals with a history of TBI was reported in 5 studies (described in 6 publications). These results are summarized in Table 10. Frequency of strabismus and cranial nerve palsy was rare in most studies, ranging from 0% to 11% in 3 studies19,24,27 though one study reported that 37.5% of Veterans with TBI history had strabismus diagnosed during an ocular exam. 9,21 One study reported similar rates of strabismus and other disorders of binocular eye movement in Veterans with TBI history compared to similar controls (0.6% vs 0.4%, respectively).19

Table 10 Strabismus and Cranial Nerve Palsy in Individuals with TBI History

Citation | Outcome measure | Prevalence estimates (stratified if available) | P value | Effect size (95% CI)
Brahm, 2009^17^ | NR | Inpatient: 17/68 (25.0%) Outpatient: 9/124 (7.3%) Blast, inpatient: 14/57 (24.6%) Non-blast, inpatient: 3/11 (27.3%) Blast, outpatient: 8/112 (7.1%) Non-blast, outpatient: 1/12 (8.3%) | NR | NR
Dougherty, 2011^19^ | ICD-9-CM code 378 “Strabismus and other disorders of binocular eye movements” | 5/837 (0.6%) No TBI Control: 5/1417 (0.4%) | NR | NR
Goodrich, 2013^9^ Goodrich, 2013^21^ | Ocular exam categorized by type of tropia (abnormal binocular eye position) | 33/88 (37.5%) PTSD: 10/38 (26.3%) No PTSD: 23/50 (46.0%) Blast: 12/42 (28.6%) No Blast: 21/46 (45.7%) | PTSD vs no PTSD: p = .10 Blast vs No Blast: p = .125 | PTSD vs no PTSD: chi-square = 2.78
Lew, 2007^24^ | NR; strabismus assessed at comprehensive eye exam | 7/62 (11%) | NR | NR
Stelmack, 2009^27^ | NR; strabismus | 3/103 (3%) | NR | NR
Stelmack, 2009^27^ | Cranial Nerve Palsy or Disorder diagnosed by oculomotor function examination | 0/88 (0%) | NR | NR

Note. TBI = Traumatic Brain Injury; NR = Not Reported; PTSD = Post-traumatic Stress Disorder.

Two studies report frequencies of strabismus and cranial nerve palsy in those with TBI history stratified by patient status. Brahm and colleagues report higher frequencies for inpatients (25.0%) than outpatients (7.3%), though they do not report statistical significance. Their results were similar after subanalysis by mechanism of injury.17 Goodrich and colleagues report non-significantly different rates of strabismus and cranial nerve palsy stratified by mechanism of injury and PTSD diagnosis in a sample of PRC inpatients.9,21

### Visual Field Defect

Visual field defects were assessed in a variety of ways in 5 included studies.17-20,27 All reported low frequency of visual field defects in Veterans with TBI history (6% or less) with the exception of one study by Brahm and colleagues which reported rates of 3.2% and 38.8% for outpatient and inpatient groups, respectively.17 Dougherty and colleagues reported similar rates for TBI and control groups.19 Results are reported in Table 11.

Table 11 Visual Field Defect in Individuals with TBI History

Citation | Outcome measure | Prevalence estimates (stratified if available)
Brahm, 2009^17^ | Confrontation or Goldmann | 38.8% inpatient, 3.2% outpatient
Bulson, 2012^18^ | Diagnosed visual field defect during eye clinic evaluation | 2/100 (2%)
Dougherty, 2011^19^ | ICD-9-CM code 377 “Disorders of optic nerve and visual pathways” | 1/837 (0.1%) No TBI Control: 4/1417 (0.3%)
Goodrich, 2007^20^ | Paracentral Scotoma assessed by confrontation or Goldmann visual field testing | Right eye: 0/50 (0.0%) Left eye: 2/50 (4.0%)
Goodrich, 2007^20^ | Visual field defect assessed by confrontation or Goldmann visual field testing | Right eye: 3/50 (6.0%) Left eye: 3/50 (6.0%)
Goodrich, 2007^20^ | Hemianopsia, Left, with Macular Sparing assessed by confrontation or Goldmann visual field testing | Right eye: 3/50 (6.0%) Left eye: 4/50 (8.0%)
Goodrich, 2007^20^ | Hemianopsia, Left, with Macular Splitting assessed by confrontation or Goldmann visual field testing | Right eye: 0/50 (0.0%) Left eye: 1/50 (2.0%)
Goodrich, 2007^20^ | Hemianopsia, Right, with Macular Sparing assessed by confrontation or Goldmann visual field testing | Right eye: 0/50 (0.0%) Left eye: 1/50 (2.0%)
Goodrich, 2007^20^ | Quadrantopsia, Left Inferior assessed by confrontation or Goldmann visual field testing | Right eye: 1/50 (2.0%) Left eye: 0/50 (0.0%)
Goodrich, 2007^20^ | Quadrantopsia, Left Superior assessed by confrontation or Goldmann visual field testing | Right eye: 1/50 (2.0%) Left eye: 0/50 (0.0%)
Stelmack, 2009^27^ | Visual field defect assessed by confrontation or Goldmann visual field testing | 5/88 (6%)
Stelmack, 2009^27^ | Optic Nerve and Visual Pathways Disorders assessed by confrontation or Goldmann visual field testing | 2/88 (2%)

Note. TBI = Traumatic Brain Injury; NR = Not Reported. No p values or effect sizes were reported.

### Visual Impairment or Dysfunction

Various aspects of visual impairment or dysfunction not previously categorized in this report were reported in the body of included literature. Three studies reported visual impairment diagnoses17-19 while 8 studies (described in 9 papers) described self-reported visual impairment.9,17,18,21-23,25-27 The variety of visual impairment/dysfunction and assessment tools precludes concise synthesis of data from this group of studies, though individual study results are reported in Table 12. One study described changes in self-reported visual impairment over time in a population of Canadian civilian adults who had sustained a TBI in a motor vehicle crash.22 This study documents a decline in self-reported visual symptoms from 6 weeks to 12 months following injury.

Table 12 Visual Impairment or Dysfunction in Individuals with TBI History

Citation | Outcome measure | Prevalence estimates or Mean (SD) (stratified if available) | Prevalence estimates or Mean (SD) for control group (if available) | P value | Effect size (95% CI)
Visual Impairment or Dysfunction, Diagnosed
Brahm, 2009^17^ | Visual acuity assessed by Feinbloom chart at 10 feet, Snellen worse than 20/60 | Inpatient: 14/63 (23.2%) Outpatient: 2/124 (1.6%) Blast, inpatient: 11/54 (20.4%) Non-blast, inpatient: 3/9 (33.3%) Blast, outpatient: 2/112 (1.8%) Non-blast, outpatient: 0/12 (0.0%) | NR | NR | NR
Bulson, 2012^18^ | Diagnosed uncorrected refractive error during eye clinic evaluation | 22/100 (22%) | NR | NR | NR
Dougherty, 2011^19^ | ICD-9-CM code 369 “Blindness and low vision” | 3/837 (0.4%) | 2/1417 (0.1%) | NR | NR
Dougherty, 2011^19^ | ICD-9-CM code 378 “Other disorders of eye” | 5/837 (0.6%) | 5/1417 (0.4%) | NR | NR
Dougherty, 2011^19^ | ICD-9-CM code 368 “Visual Disturbances” | 16/837 (1.9%) | 8/1417 (0.6%) | 0.003 | chi-square = 9.063
Visual Impairment or Dysfunction, Self-Reported
Brahm, 2009^17^ | Self-reported visual impairment | Inpatient: 46/61 (75.4%) Outpatient: 94/124 (75.8%) Blast, inpatient: 41/53 (77.4%) Non-blast, inpatient: 5/8 (62.5%) Blast, outpatient: 85/112 (75.9%) Non-blast, outpatient: 9/12 (75.0%) | NR | NR | NR
Bulson, 2012^18^ | NSI-22, self-report measure item assessing “blur/trouble seeing” with score of 2 or greater | 47/100 (47%) | NR | NR | NR
Goodrich, 2013^9^ Goodrich, 2013^21^ | Self-reported blurred vision, hazy vision, or other general visual symptoms | 67/100 (67.0%) PTSD: 31/41 (75.6%) No PTSD: 36/59 (61.0%) No Blast: 34/49 (69.4%) Blast: 33/50 (66.0%) | NR | PTSD vs no PTSD: p = .19 Blast vs No Blast: p = “non-significant” | PTSD vs no PTSD: chi-square = 1.72
Hartvigsen, 2014^22^ | Self-reported “vision problems” | 6 weeks: 276/1716 (19.3) 3 months: 232/1716 (16.9) 6 months: 208/1716 (16.4) 9 months: 178/1716 (15.9) 12 months: 156/1716 (14.4) | NR | NR | NR
Lemke, 2013^23^ | 25-item National Eye Institute Visual Functioning Questionnaire (VFQ-25) self-report measure | General vision mean: 69 Ocular pain mean: 81 Near activities mean: 72 Distance activities mean: 77 Social functioning mean: 85 Mental health mean: 69 Role difficulties mean: 69 Dependency mean: 75 Driving mean: 73 Color vision mean: 89 Peripheral vision mean: 71 Composite score mean: 75 | General vision mean: 83 Ocular pain mean: 90 Near activities mean: 92 Distance activities mean: 93 Social functioning mean: 99 Mental health mean: 92 Role difficulties mean: 93 Dependency mean: 92 Driving mean: 99 Color vision mean: 87 Peripheral vision mean: 98 Composite score mean: 97 | Healthy control composite score: p < .001 Comparisons to patients with diabetes mellitus, glaucoma, and macular degeneration: p < .001 Comparisons to patients with dry eye: p < .05 Comparisons to patients with macular telangiectasia and cataract: p = “non-significant” | NR
Lew, 2011^26^ | NSI-22, self-report measure item assessing “vision problems, blurring, trouble seeing.” | 44.5% Vision only: 9.9% Vision and hearing: 34.6% Blast: 44.2% Blast, vision only: 8.8% Blast, vision and hearing: 35.4% No blast: 46.0% No blast, vision only: 15.7% No blast, vision and hearing: 30.3% | Blast: 33.1% Blast, vision only: 8.5% Blast, vision and hearing: 24.6% No blast: 35.9% No blast, vision only: 13.2% No blast, vision and hearing: 22.7% | Regression predicting visual impairment from demographics, hearing, TBI, and blast: p < .0001 | TBI accounted for .69% and blast for .14% of variance in vision impairment adjusting for demographics and hearing impairment.
Lew, 2009^25^ | Combination of vision status self-report before/after injury; distance and near visual acuity measurements; visual field status; binocular vision status; and other vision measures, including reading speed and comprehension assessments. | 41/62 (66%) Vision only: 21 (33.9%) Vision and hearing: 20 (32.3%) | NR | NR | NR
Stelmack, 2009^27^ | NSI-22, self-report measure item assessing “vision problems, blurring, trouble seeing.” | 55/88 (63%) | NR | NR | NR

Note. TBI = Traumatic Brain Injury; NR = Not Reported; PTSD = Post-traumatic Stress Disorder.

One study reported that IDC-9-CM diagnosis of visual disturbances was significantly more common in those with TBI history compared to a control group without a TBI history that had similar characteristics (1.9% vs 0.6%, p = .003).19 Another study compared visual impairment assessed using the 25-item National Eye Institute Visual Functioning Questionnaire (VFQ-25) self-report measure in Veterans with data from healthy controls obtained from another published paper. The authors note that Veterans with TBI history reported significantly worse functioning on this measure compared with controls (p = .001), though the control group was likely very different from cases in ways other than just TBI history.23 Lew and colleagues compared self-reported visual symptoms in previously deployed Veterans with and without TBI history. After adjustment for demographic characteristics and hearing impairment, the authors reported that TBI and blast accounted for 0.69% and 0.14% of the variance in self-reported vision impairment.26

## KEY QUESTION 2 What are the types of visual dysfunction reported by individuals who have been diagnosed with a TBI and are presenting to Eye Care clinics?

### Summary of Findings

Four studies met inclusion criteria for Key Question 2. All 4 provided case series data. Study and sample characteristics are reported in Table 2. Results are presented by outcome in Table 13, which includes presentation of results stratified by or adjusted for key modifiers such as mechanism of injury and inpatient versus outpatient status, when available. One study reports data from civilians16 though 3 others report data from Veterans treated within the VA.18,27,28 Two of the VA studies also provided data relevant to Key Question 1, describing frequency of visual dysfunction in populations of Veterans with TBI history, while also reporting data solely from those who were seen in eye care clinics.15,24 As expected, the rates of visual dysfunction for Veterans seen in eye care clinics are higher than rates for unselected samples (ie, samples not selected studies based on visual dysfunction). Studies meeting inclusion criteria for Key Question 2 reported similar types of visual dysfunction as studies included for Key Question 1.

Table 13 Visual Dysfunction in Individuals with TBI Presenting to an Eye Care Clinic

Citation | Outcome measure | Frequencies (stratified if available) | P value | Effect size (95% CI)
Accommodation Dysfunction and Refractive Errors
Bulson, 2012^18^ | Diagnosed accommodative dysfunction during eye clinic evaluation | 3/23 (13%) | NR | NR
Magone, 2014^28^ | Diagnosed when the lower limit of the expected value for the patient's age was abnormal according to Hofstetter's formula | 7/31 (23%) | NR | NR
Stelmack, 2009^27^ | NR | 17/36 (47%) | NR | NR
Convergence Insufficiency or Dysfunction
Alvarez, 2012^16^ | Near point of convergence was measured with an approaching near target. | 130/557 (23.3%) MVC: 90/395 (22.7%) Fall: 17/82 (20.7%) Strike/blow: 15/51 (29.4%) Sports: 2/14 (14.3%) Other: 6/15 (40.0%) Inpatient: 63/270 (23.3%) Outpatient: 67/287 (23.3%) | p = 0.36 (mechanism of injury) | chi-square = 4.4 (mechanism of injury)
Magone, 2014^28^ | Diagnosed when there was exophoria greater at near compared with distance, an abnormal near point of convergence (NPC), and positive fusional vergence. NPC measures the ability to maintain binocularly with increased accommodative and vergence demand. NPC was measured with the red lens method. A red lens was placed in front of patient's right eye and the muscle light was moved close to the patient until the break (2 lights) was reported or a break in fusion was observed by the examiner. A remote NPC with a break of greater than 8 cm and recovery greater than 12 cm was considered abnormal. | 8/31 (25%) | NR | NR
Stelmack, 2009^27^ | NR | 10/36 (28%) | NR | NR
Diplopia
Magone, 2014^28^ | NR | 4/31 (13%) | NR | NR
Stelmack, 2009^27^ | NR | 3/36 (8%) | NR | NR
Dry Eye Syndrome
Alvarez, 2012^16^ | Slit-lamp evaluation of the corneal tear layer; portable blue filter with fluorescent staining was used for some inpatients. | 58/557 (10.4%) Inpatient: 32 (11.9%) Outpatient: 26 (9.1%) | NR | NR
Bulson, 2012^18^ | Diagnosed dry eye syndrome during eye clinic evaluation | 2/23 (9%) | NR | NR
Nystagmus or Fixation Dysfunction
Alvarez, 2012^16^ | Findings outside the normal range on oculomotor examination | 22/557 (3.9%) Inpatient: 10 (3.7%) Outpatient: 12 (4.2%) | NR | NR
Stelmack, 2009^27^ | NR | 0/36 (0%) | NR | NR
Photosensitivity, Photophobia, or Light Sensitivity
Alvarez, 2012^16^ | Patient sensitivity to direct light stimulation during pupil examination | 56/557 (10.1%) Inpatient: 19 (7.0%) Outpatient: 35 (12.2%) | p = .04 (inpatient; non-significant after Bonferroni adjustment) | z = 2.06 (inpatient)
Bulson, 2012^18^ | Diagnosed photosensitivity during eye clinic evaluation | 5/23 (22%) | NR | NR
Magone, 2014^28^ | Self-reported by patient | 17/31 (55%) | NR | NR
Pursuit or Saccadic Dysfunction
Alvarez, 2012^16^ | Patients asked to track a transilluminator or other visual target. Pursuit and saccadic movements were noted to be smooth and accurate, or had fixation losses, or abnormal saccades, respectively (or were unable to perform the test) | 42/557 (7.5%) Inpatient: 23 (8.5%) Outpatient: (19 (6.6%) | NR | NR
Stelmack, 2009^27^ | NR | 2/36 (6%) | NR | NR
Strabismus and Cranial Nerve Palsy
Alvarez, 2012^16^ | Cranial Nerve Palsy or Disorder diagnosed by oculomotor function examination | Third cranial nerve: 33 (5.9%) Inpatient, third: 19 (7.0%) Outpatient, third: 14 (4.9%) Fourth cranial nerve: 56 (10.1%) Inpatient, fourth: 28 (10.4%) Outpatient, fourth: 28 (9.8%) Sixth cranial nerve: 24 (4.3%) Inpatient, sixth: 19 (7.0%) Outpatient, sixth: 35 (12.2%) | p = .002 (inpatient, sixth cranial nerve palsy) | z = 3.08 (inpatient, sixth cranial nerve palsy)
Stelmack, 2009^27^ | NR; strabismus | 3/36 (8%) | NR | NR
Stelmack, 2009^27^ | Cranial Nerve Palsy or Disorder diagnosed by oculomotor function examination | 0/36 (0%) | NR | NR
Visual Field Defect
Alvarez, 2012^16^ | Homonymous Hemianopsia assessed by confrontation or Humphrey Field Test, depending on patient functionality | Right: 21/557 (3.8%) Left: 24/557 (4.3%) | NR | NR
Alvarez, 2012^16^ | Quadrantopsia assessed by confrontation or Humphrey Field Test, depending on patient functionality | 28 (15.7%) | NR | NR
Bulson, 2012^18^ | Diagnosed visual field defect during eye clinic evaluation | 2/23 (9%) | NR | NR
Stelmack, 2009^27^ | Visual field defect assessed by confrontation or Goldmann visual field testing | 5/36 (14%) | NR | NR
Stelmack, 2009^27^ | Optic Nerve and Visual Pathways Disorders assessed by confrontation or Goldmann visual field testing | 2/36 (6%) | NR | NR
Visual Impairment or Dysfunction
Alvarez, 2012^16^ | Visual acuity assessed by Snellen (eye chart) with targets appropriate to patient's cognitive functioning | >/= 20/60 = 473/557 (84.9%) 20/70-20/100 = 16/557 (2.9%) <20/100 = 27/557 (4.8%) No light perception = 4 (.07%) Patient unable to respond = 37 (6.6%) | NR | NR
Bulson, 2012^18^ | Diagnosed uncorrected refractive error during eye clinic evaluation | 22/23 (96%) | NR | NR
Magone, 2014^28^ | Distance visual acuity was measured using the projected Snellen eye chart | 21/31 (68%) | NR | NR

Note. TBI = Traumatic Brain Injury; NR = Not Reported; Hofstetter's formula: 18.5 - (0.30 * patient age in years)

Given that Key Question 2 relates to types of visual dysfunction seen in eye care clinics, quality considerations are primarily related to generalizability of population and setting as summarized in Key Question 1. One included study reports on TBI in civilian populations16; the other 3 studies providing data relevant to Key Question 2 report data from Veterans presenting to eye clinics in conjunction with VA care including PNS and post-deployment clinics and referrals.18,27,28