# REFERENCES

1 Coronado VG, McGuire LC, Sarmiento K, et al. Trends in Traumatic Brain Injury in the U.S. and the public health response: 1995–2009. Journal of Safety Research. 2012;43(4):299-307. [pmid: 23127680].
2 United States Census Bureau. USA Quick Facts. http://quickfacts.census.gov/qfd/states/00000.html. August 29 2014. 2014.
3 Hoge CW, McGurk D, Thomas JL, Cox AL, Engel CC, Castro CA. Mild Traumatic Brain Injury in U.S. Soldiers Returning from Iraq. New England Journal of Medicine. 2008;358(5):453-463. [pmid: 18234750].
4 Epidemiology Program, Post-Deployment Health Group, Office of Public Health, Veterans Health Administration, Affairs DoV. Analysis of VA Health Care Utilization among Operation Enduring Freedom, Operation Iraqi Freedom, and Operation New Dawn Veterans, from 1st Qtr FY 2002 through 2nd Qtr FY 2014. Vol Retrieved from http://www.publichealth.va.gov/docs/epidemiology/healthcare-utilization-report-fy2014-qtr2.pdf. Washington, DC. 2014.
5 Carroll LJ, Cassidy JD, Cancelliere C, et al. Systematic Review of the Prognosis After Mild Traumatic Brain Injury in Adults: Cognitive, Psychiatric, and Mortality Outcomes: Results of the International Collaboration on Mild Traumatic Brain Injury Prognosis. Archives of physical medicine and rehabilitation. 2014;95(3, Supplement):S152-S173. [pmid: 24581903].
6 O'Neil ME, Carlson DF, Storzbach D, et al. Factors Associated with Mild Traumatic Brain Injury in Veterans and Military Personnel: A Systematic Review. Journal of the International Neuropsychological Society. 2014;20(03):249-261. [pmid: 24622505].
7 Kelts EA. Traumatic brain injury and visual dysfunction: a limited overview. NeuroRehabilitation. 2010;27(3):223-229. [pmid: 21098990].
8 Cockerham GC, Lemke S, Glynn-Milley C, Zumhagen L, Cockerham KP. Visual performance and the ocular surface in traumatic brain injury. The ocular surface. Jan. 2013;11(1):25-34. [pmid: 23321357].
9 Goodrich GL, Flyg HM, Kirby JE, Chang CY, Martinsen GL. Mechanisms of TBI and visual consequences in military and veteran populations. Optometry and vision science : official publication of the American Academy of Optometry. Feb. 2013;90(2):105-112. [pmid: 23314131].
10 Wainapel SF. Vision Rehabilitation: an overlooked subject in physiatric training and practice. Commentary. American Journal of Physical Medicine & Rehabilitation. 1995;74(4):313-314. [pmid: 7632390].
11 U.S. Department of Veterans Affairs VHA. Kussman MJ. Performance of Traumatic Brain Injury Specific Ocular Health and Visual Functioning Examinations for Polytrauma Rehabilitation Center Patients. Washington, D.C. DVA VHA. October. 20. 2008. VHA Directive 2008-065. 2008.
12 Barker F II, Ciuffreda KJ, Jacobs J, et al. Traumatic Brain Injury Detection using Oculomotor and Eye Movement Tracking. A Technical Working Group Critical Review. Group OTW, editor. Version 1.3. December. 3. 2013. 2013.
13 Adams E. Visual problems in traumatic brain injury: a systematic review of sequelae and interventions for the Veteran populations. Department of Veterans Affairs VHA Office of Patient Care Services Technology Assessement Program. 2009.
14 Hayden JA, Côté P, Bombardier C. Evaluation of the Quality of Prognosis Studies in Systematic Reviews. Annals of Internal Medicine. 2006;144(6):427-437. [pmid: 16549855].
15 Guyatt G, Oxman AD, Akl EA, et al. GRADE guidelines: 1. Introduction—GRADE evidence profiles and summary of findings tables. Journal of clinical epidemiology. 2011;64(4):383-394. [pmid: 21195583].
16 Alvarez TL, Kim EH, Vicci VR, Dhar SK, Biswal BB, Barrett AM. Concurrent vision dysfunctions in convergence insufficiency with traumatic brain injury. Optometry and vision science : official publication of the American Academy of Optometry. Dec. 2012;89(12):1740-1751. [pmid: 23190716].
17 Brahm KD, Wilgenburg HM, Kirby J, Ingalla S, Chang CY, Goodrich GL. Visual impairment and dysfunction in combat-injured servicemembers with traumatic brain injury. Optometry and vision science : official publication of the American Academy of Optometry. Jul. 2009;86(7):817-825. [pmid: 19521270].
18 Bulson R, Jun W, Hayes J. Visual symptomatology and referral patterns for Operation Iraqi Freedom and Operation Enduring Freedom veterans with traumatic brain injury. Journal of rehabilitation research and development. 2012;49(7):1075-1082. [pmid: 23341280].
19 Dougherty AL, MacGregor AJ, Han PP, Heltemes KJ, Galarneau MR. Visual dysfunction following blast-related traumatic brain injury from the battlefield. Brain injury : [BI]. 2011;25(1):8-13.
20 Goodrich GL, Kirby J, Cockerham G, Ingalla SP, Lew HL. Visual function in patients of a polytrauma rehabilitation center: A descriptive study. Journal of rehabilitation research and development. 2007;44(7):929-936. [pmid: 18075950].
21 Goodrich GL, Martinsen GL, Flyg HM, Kirby J, Garvert DW, Tyler C. Visual function, traumatic brain injury, and post-traumatic stress disorder. Journal of Rehabilitation Research & Development. 2013.
22 Hartvigsen J, Boyle E, Cassidy JD, Carroll LJ. Mild traumatic brain injury after motor vehicle collisions: what are the symptoms and who treats them? A population-based 1-year inception cohort study. Archives of physical medicine and rehabilitation. Mar. 2014;95(3 Suppl):S286-294. [pmid: 24581914].
23 Lemke S, Cockerham GC, Glynn-Milley C, Cockerham KP. Visual Quality of Life in Veterans With Blast-Induced Traumatic Brain Injury. JAMA ophthalmology. Oct. 17. 2013.
24 Lew HL, Poole JH, Vanderploeg RD, et al. Program development and defining characteristics of returning military in a VA Polytrauma Network Site. Journal of rehabilitation research and development. 2007;44(7):1027-1034. [pmid: 18075959].
25 Lew HL, Garvert DW, Pogoda TK, et al. Auditory and visual impairments in patients with blast-related traumatic brain injury: Effect of dual sensory impairment on Functional Independence Measure. Journal of rehabilitation research and development. 2009;46(6):819-826. [pmid: 20104405].
26 Lew HL, Pogoda TK, Baker E, et al. Prevalence of dual sensory impairment and its association with traumatic brain injury and blast exposure in OEF/OIF veterans. The Journal of head trauma rehabilitation. Nov-Dec. 2011;26(6):489-496. [pmid: 21386715].
27 Stelmack JA, Frith T, Van Koevering D, Rinne S, Stelmack TR. Visual function in patients followed at a Veterans Affairs polytrauma network site: an electronic medical record review. Optometry (St. Louis, Mo.). Aug. 2009;80(8):419-424.
28 Magone TM, Kwon E, Shin SY. Chronic visual dysfunction after blast-induced mild traumatic brain injury. Journal of rehabilitation research and development. 2014;51(1):71-80. [pmid: 24805895].