# METHODS

## TOPIC DEVELOPMENT

This topic was submitted to the ESP Coordinating Center for development by Mary G. Lawrence, MD, MPH, Interim Director, VA/DoD Vision Center of Excellence (VCE), in collaboration with other key stakeholders Felix Barker, Associate Director, Research, Rehabilitation and Reintegration, Vision Center of Excellence, Salisbury VAMC; Christopher Moore, PhD, VA Scientific Program Manager for Sensory Systems and Communication Disorders Program; and Stuart W. Hoffman, PhD, Scientific Program Manager for Brain Injury, Rehabilitation Research and Development Service, TBI Point of Contact and Subject Matter Expert, Office of Research and Development. We also received input from a technical expert panel (see Appendix A).

The goal of this evidence report is to summarize current evidence examining the prevalence and types of visual dysfunction and impairment among patients diagnosed with TBI. Understanding the scope of visual disorders among these populations will aid the VHA in determining appropriate screening strategies for visual dysfunction and impairment among returning Veterans diagnosed with TBI. Better understanding of the specific visual dysfunctions that may be associated with TBI will also enable appropriate intervention within the vision care system. A secondary goal is to develop a strategy for the monitoring of outcomes from the assessment and management of TBI-related visual disorders, thus potentially producing improved outcomes in the overall rehabilitation and reintegration of affected Veterans.

The Key Questions, which were developed in concert with the stakeholders, are as follows:

Key Question 1: What is the prevalence or incidence of visual dysfunction in a general population of individuals who have been diagnosed with a TBI?

Key Question 2: What are the types of visual dysfunction reported by individuals who have been diagnosed with a TBI and are presenting to eye care clinics?

## SEARCH STRATEGY

We identified an existing systematic review of visual dysfunction in patients with TBI published in 2009 by Adams and colleagues.13 Because of overlapping Key Questions and inclusion criteria in that review and our current report, we based our search prior to 2009 on the studies included in the Adams 2009 review.13 We also searched Medline (OVID), PsychINFO (OVID), and the Cochrane Register of Controlled Trials (OVID), SPORTDiscus, Rehabilitation & Sports Medicine Source (EBSCO), and Rehabdata (National Rehabilitation Information Center) for studies published between January 1st, 2009 and March 27th, 2014. The search strategy is reported in Appendix B. We obtained additional articles from systematic reviews, reference lists of pertinent studies, reviews, editorials, and by consulting clinical and research experts. All citations were imported into an electronic database (EndNote X4).

## STUDY SELECTION

We included studies reporting outcomes in patients with a history of TBI diagnosis of any severity. We included studies using a definition of TBI consistent with that used in the Adams 2009 review, which is inclusive of cases meeting both American Congress of Rehabilitation Medicine (ACRM) and VA/DoD criteria: “This report will include clinical research of TBI caused by detonation or other mechanisms of diffuse closed head injury such as diffuse axonal injury from motor vehicle accidents, falls and sport/recreational activities that are likely to resemble the types of exposure experienced by our newest Veteran population; it will exclude causes of focal brain injury such as stroke, infection, and tumors.”13 Studies reporting only data on patients with ocular injuries were excluded, though studies that included a portion of patients with ocular injuries were included. Patients under 5 years of age were excluded. For Key Question 1, but not Key Question 2, we excluded studies reporting a population selected for the study based even in part on visual dysfunction.

We included visual dysfunction and outcomes that would likely be diagnosed or treated in an eye care clinic (eg, oculomotor disorders, visual acuity loss, strabismus, convergence insufficiency, diplopia, hemianopsia, other homonymous visual field defects, photosensitivity, nystagmus). We excluded physical injuries to the eye such as open globe injuries or retinal hemorrhage; shaken baby syndrome; visually administered cognitive assessments that do not assess a primarily visual outcome (eg, visual agnosia, spatial neglect, visuospatial abilities, visual scanning, visually administered tests primarily assessing memory, executive functioning including Stroop tests, academic achievement, reading, writing, math, language abilities, reaction time, attention, or concentration); vision-related outcomes that are primarily neurocognitive in nature and would not be diagnosed or treated in an eye care clinic; brain imaging results not reporting associated visual dysfunctions; and self-reported global vision difficulties reported on general screening tools (eg, single items on screening questionnaires assessing vision problems, blurred vision, double vision, trouble seeing, or light sensitivity). Research conducted at any length of time since injury was included.

For Key Question 1, included settings were primary care settings, school or athletic programs, or any settings serving a general population that is not being examined for suspected TBI-related vision symptoms. Studies of prevalence or incidence were included if they were cohort, case-control, controlled trials, or studies with a control or comparison group including self as control. Studies with fewer than 50 participants with a history of TBI were excluded.

For Key Question 2, included settings were eye care clinics. All study designs were considered. Consistent with the inclusion criteria for the Adams review, studies reporting type of visual dysfunction in eye care clinic populations were excluded if they reported fewer than 10 cases with visual dysfunction.

We published our key questions and abstract online so that they were available for public review.

## DATA ABSTRACTION

We abstracted data from each included study on study design; sample size; TBI definition; participant selection and characteristics; key moderators and potential confounders including mechanism of injury, time since injury, and ocular injuries; outcome measures; and results. These data are reported in Tables 3 to 12. Data was abstracted by one investigator and reviewed for accuracy by at least one additional investigator.

## QUALITY ASSESSMENT

We assessed the quality of included studies pertaining to both Key Questions. Because the focus of this review is on estimating prevalence, we examined study quality using the Quality in Prognostic Studies (QUIPS) study appraisal tool14 and highlight factors such as sample selection and outcome assessment which have the potential to impact prevalence estimates. Study data relevant to risk of bias was extracted by one investigator and reviewed for accuracy by at least one additional investigator. Specific study quality factors are summarized as relevant for each Key Question.

## DATA SYNTHESIS

We constructed evidence tables showing the study characteristics and results for all included studies organized by outcome. We critically analyzed studies to compare their characteristics, methods, and findings. We compiled a summary of findings for each outcome category and key question, and drew conclusions based on qualitative synthesis of the findings. We did not combine the studies in a quantitative manner via meta-analysis because of the heterogeneity of study characteristics, particularly because studies did not report proportions of patients with different levels of TBI severity and those with ocular injuries, both of which likely influence the outcomes of interest. The synthesis was conducted by the principal investigator, though all results were reviewed with the team of investigators to review and obtain consensus on the reported findings.

## RATING THE BODY OF EVIDENCE

Key questions focus on prevalence estimates and common types of visual dysfunctions treated in clinical settings; therefore, we did not formally rate the strength of the body of evidence as most rating schemes are applicable to strength of evidence for interventions or diagnostic tests (eg, Grading of Recommendations Assessment, Development, and Evaluation (GRADE) criteria).15

## PEER REVIEW

A draft version of this report was reviewed by 8 technical experts and clinical leaders. Their comments and the authors' responses are presented in Appendix C.