# INTRODUCTION

There is a high prevalence of traumatic brain injury (TBI) in both military and non-military populations. The Centers for Disease Control and Prevention reported that, in 2009, approximately 3.5 million people (just over 1% of the population) received healthcare treatment related to a TBI in the United States (U.S.).1,2 Researchers estimate that approximately 15% of Operation Enduring Freedom/Operation Iraqi Freedom/Operation New Dawn (OEF/OIF/OND) Service Members have incurred TBI during deployment, equating to 390,000 of the 2.6 million who have deployed through 2014.^3,4^ The risk that patients with a history of TBI will experience symptoms over the long-term depends in part on the severity of injury. However, many patients with even mild TBI (mTBI) present with long-term symptoms, though it is unclear whether these symptoms are directly attributable to the brain injury.5,6

Vision-related symptoms are increasingly recognized as one possible long-term sequelae of TBI. Given that intact vision depends on portions of the brain interacting in complex ways, there are multiple potential mechanisms through which trauma can result in visual deficits. In brief, the visual pathways are organized in afferent and efferent arcs. The afferent arc receives and processes visual stimuli while the efferent arc moves the eyes in the direction of the object of visual regard. In the midst of this complex milieu, there exist anticipatory and interpretive systems which add neurocognitive input to the visual imagery.7 TBI can cause a wide variety of injuries to the visual system including anterior and posterior visual pathway damage affecting visual acuity, color vision, and resultant visual fields defects. Cranial nerve injuries can manifest as diplopia and nystagmus due to oculomotor dysfunction.8 Patients with TBI history may experience photosensitivity or difficulty reading, or may exhibit abnormal fixation and accommodative dysfunction.9

Although vision is an important sensory modality for critical activities of daily living (ADLs), the diagnosis and treatment of functional vision deficits has been inconsistent.10 In 2008, the VA issued a policy statement requiring all TBI patients seen at Polytrauma Rehabilitation Centers (PRCs) be seen by an optometrist or ophthalmologist for a visual health examination, but the vision screening and treatment of other Veterans and U.S. Service members treated outside of PRCs varies.11 Additionally, there are ongoing efforts in the VA and Department of Defense (DoD) to determine relationships among visual symptoms and TBI history, including efforts to examine oculomotor tracking as a way to detect mTBI.12 To help inform VA policymakers and clinicians responsible for TBI program planning and service delivery, we conducted a systematic review of the literature examining the prevalence and type of visual dysfunction in military and non-military populations with a history of TBI.