# EXECUTIVE SUMMARY

## INTRODUCTION

In 2009, approximately 3.5 million people sought treatment related to a traumatic brain injury (TBI) in the United States (U.S.), just over 1% of the U.S. population. Researchers estimate that approximately 15% of Operation Enduring Freedom/Operation Iraqi Freedom/Operation New Dawn (OEF/OIF/OND) U.S. Service Members have incurred TBI during deployment. This equates to 390,000 of the 2.6 million Service Members who have deployed as of 2014. Given that intact visual functioning depends on portions of the brain interacting in complex ways, there are multiple potential mechanisms through which TBI can result in visual dysfunction. To provide relevant data for policymakers, optometrists, ophthalmologists, rehabilitation specialists, and others who provide services for Veterans with TBI history, we conducted a systematic review of the prevalence and types of visual dysfunction in individuals with a history of TBI.

Key Questions are:

Key Question 1: What is the prevalence or incidence of visual dysfunction in a general population of individuals who have been diagnosed with a TBI?

Key Question 2: What are the types of visual dysfunction reported by individuals who have been diagnosed with a TBI and are presenting to eye care clinics?

## METHODS

We used a previous systematic review on visual problems in traumatic brain injury to identify studies published prior to 2009. We searched Medline (OVID), PsychINFO (OVID), the Cochrane Register of Controlled Trials (OVID), SPORTDiscus, Rehabilitation & Sports Medicine Source (EBSCO), and Rehabdata (National Rehabilitation Information Center) for studies published between January 1st, 2009 and March 27th, 2014. We included studies reporting visual dysfunctions likely to be treated in eye care clinics in patients over 5 years of age with a history of TBI diagnosis of any severity; studies included for Key Question 1 were based on unselected populations (ie, participants not selected for inclusion in the study based on visual dysfunction). Data abstraction and quality assessment were dual reviewed by investigators. Standard quality criteria were applied as relevant for each Key Question. We provide both qualitative synthesis of results and evidence tables for each type of visual dysfunction identified.

## RESULTS

We examined 1299 titles and abstracts, selecting 118 articles for full-text review. We report the results of 12 primary studies meeting inclusion criteria for Key Question 1, and 4 primary studies that provide data for Key Question 2. Study results were grouped and synthesized according to common sample characteristics. Evidence from a large retrospective cohort study of U.S. Service Members who were diagnosed with visual dysfunction and treated in military healthcare settings suggests that visual dysfunction is infrequently diagnosed in unscreened populations of U.S. Service Members with TBI history, occurring in less than 1% of the population in most cases. Disorders of accommodation and refraction are slightly more common, with a frequency of 7.3% in this population. Other studies included in this review focused on Veterans seen at the Department of Veterans Affairs (VA) Polytrauma Rehabilitation Centers (PRCs) and Polytrauma Network Sites (PNSs). Visual dysfunction was much more frequent in these populations, with estimates of over 50% for many conditions such as accommodation and refraction disorders, convergence insufficiency or dysfunction, dry eye syndrome, photosensitivity, pursuit or saccadic dysfunction, and self-reported visual impairments. Table 1 summarizes results across studies.

Table 1 Summary of Findings: Ranges of Visual Dysfunction Frequencies Across Studies

| Studies including patients with TBI history [underlined: regardless] of current symptoms | | Studies including patients with TBI history who [underlined: all] have current symptoms
Outcome | Unscreened | Screened | Screened
Accommodation Dysfunction and Refractive Errors | 7.3% (1 study) | 3.0% (1 study) | 19.0 - 66.7% (6 studies)
Convergence Insufficiency or Dysfunction | No studies | No studies | 11.0 - 62.5% (6 studies)
Diplopia | No studies | No studies | 3.0 - 40.0% (4 studies)
Dry Eye | 0.1% (1 study) | 2.0% (1 study) | 93.0% with one or more positive tests (1 study)
Nystagmus or Fixation Dysfunction | No studies | No studies | 0.0 - 23.4% (5 studies)
Photosensitivity, Photophobia, or Light Sensitivity | No studies | 5.0 – 54.0% (1 study, diagnosed vs self-report) | 51.0 - 59.0% (3 studies, all self-report)
Pursuit or Saccadic Dysfunction | No studies | No studies | 2.0 - 70.8% (5 studies)
Strabismus and Cranial Nerve Palsy | 0.6% (1 study) | | 0.0 - 37.5% (4 studies)
Visual Field Defect | 0.1% (1 study) | 2.0% (1 study) | 0.0% - 38.8% (3 studies)
Visual Impairment or Dysfunction, Diagnosed | 0.4% (1 study) | 22.0% (1 study) | 8.5% (1 study)
Visual Impairment or Dysfunction, Self-Reported | No studies | 8.8 - 47.0% (3 studies) | 32.2 - 77.4% (6 studies)

## CONCLUSIONS

Studies included in this review report a wide range in the frequency of visual dysfunction in people with TBI history. The range of estimates is likely due to differences in setting and patient population across studies. While some studies reported results from individuals regardless of current symptoms, many of the included studies were conducted in VA PRCs and PNSs, clinics that only serve Veterans who have current symptoms as well as other, often serious, comorbidities. Overall, visual dysfunction diagnosed in U.S. Service Members treated in military healthcare settings is uncommon, occurring in less than 1% of individuals for most disorders. However, studies of Veterans with TBI history and current symptoms who are treated in TBI rehabilitation clinics report much higher frequencies, often over 50% for many types of visual dysfunction.