# SEARCH STRATEGIES

Concept | Mesh terms | Free language terms
TBI 77364 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6) | “Brain Injuries”[Mesh] OR “Head Injuries, Closed”[Mesh] OR “Blast Injuries”[Mesh] | (“head injury” OR “head injuries” OR concussion OR concusses OR concussive OR “brain trauma” OR “head trauma” OR “traumatic Brain injury” OR “traumatic brain injuries” OR “traumatic-brain-injury OR tbi OR mtbi OR stbi OR “blast injury” OR “blast injuries” OR blast-injury)[Title/Abstract]
Vision 73480 | “Eye Movement Measurements”[Mesh] OR “Ocular Motility Disorders”[Mesh] OR “Ocular Physiological Processes”[Mesh] OR “Visual Perception”[Mesh] OR “Visual Acuity”[Mesh] OR “Eye”[Mesh] OR “Vision Disorders”[Mesh] OR “Vision, Ocular”[Mesh] | (amblyopia OR binocular vision dysfunction OR binocular vision dysfunctions OR binocular visual dysfunction OR binocular visual dysfunctions OR blind* OR blindness OR convergence insufficiency OR cranial nerve evaluation OR cranial nerve evaluations OR dark adapt* OR diplopia OR facial recognition OR fixation defect OR fixation defects OR hemianopsia OR light sensitiv* OR nystagmus OR ocular disease surface index OR ocular examination OR ocular examinations OR ocular health OR ocular migraine OR ocular migraines OR ocular pain OR ocular surface stain* OR ocular trauma OR oculo-motor disorder OR oculo-motor disorders OR oculo motor disorders OR oculo motor disorder OR ODSI OR ophthalmolog* OR optometr* OR photic stimulation | OR photosensitivities OR photosensitivity OR pursuit abnormalit* OR quadrantonopsia OR spatial neglect OR strabismus OR tear film break-up time OR tear osmolarity OR tear production OR TFBUT OR vertical heterophoria OR vision accommodation OR vision acuity OR vision acuity loss OR vision agnosia OR vision deficit OR vision deficits OR Vision disorder OR Vision disorders OR vision disturbance OR vision disturbances OR vision field defect OR vision field defect OR vision field defects OR vision field defects OR vision function OR vision motor OR vision perception OR Vision problem OR Vision problems OR vision process OR vision processes OR vision processing OR vision reflex OR vision reflexes | OR vision scanning OR vision sequelae OR vision system OR vision system dysfunction OR vision system dysfunctions OR visiospatial ability OR visual accommodation OR visual acuity OR visual acuity loss OR visual agnosia OR visual deficit OR visual deficits OR Visual disorder OR Visual disorders OR visual disturbance OR visual disturbances OR visual field defect OR visual field defects OR visual function OR visual motor OR visual perception OR Visual problem OR Visual problems OR visual process OR visual processes OR visual processing OR visual reflex OR visual reflexes OR visual scanning OR visual sequelae OR visual system OR visual system dysfunction OR visual system dysfunctions OR visuospatial abilities OR visuo-spatial abilities)[Title/Abstract]
Above Combined with AND N= 3991
Limited to 2009 and beyond N=932

Medline (PubMed) Searched March 27, 2014 from January 1st, 2009 on

Saved as “TBI EYE” final in PubMed porvaesp myNCBI account

N=932

## Additional Databases

### Cochrane Central Register of Controlled Trials (OVID)

1. exp Visual Perception/
2. exp Visual Acuity/
3. exp Eye/
4. exp Vision Disorders/
5. exp Vision, Ocular/
6. 1 or 2 or 3 or 4 or 5
7. (amblyopia or binocular visionsysfunction or binocular vision dysfunctions).mp.
8. (binocular visual dysfunction or binocular visual dysfunctions or blind*).mp.
9. (blindness or convergence insufficiency or cranial nerve evaluation or cranial nerve evaluations).mp.
10. (dark adapt* or diplopia or facial recognition or fixation defect or fixation defects).mp.
11. (hemianopsia or light sensitiv* or nystagmus or ocular disease surface index).mp.
12. (ocular examination or ocular examinations or ocular health or ocular migraine or ocular migraines).mp.
13. (ocular pain or ocular surface stain* or ocular trauma or oculo-motor disorder).mp.
14. (oculo-motor disorders or ODSI or ophtahlmolog* or optometr* or photic stimulation).mp.
15. (photosensitivities or photosensitivity or pursuit abmormalit* or quadrantonopsia).mp.
16. (spacial neglect or strabismus or tear film break-up time or tear osmolarity or tear production or tfbut).mp.
17. (vertical heterophoria or vision accomidation or vision acuity or vision acuity loss).mp.
18. (vision agnosia or vision deficit or vision deficits or vision disorder or vision disorders).mp.
19. (vision disturbance or vision disturbances or vision field defect or vision field defects or vision function or vision motor).mp.
20. (vision perception or vision problem or vision problems or vision process or vision proccesses).mp.
21. (vision proccessing or vision reflex or vision reflexes or vision scanning or vision sequelae or vision system).mp.
22. (vision system dysfunction or vision system dysfunctions or visiospacial ability or visual accomidation or visual acuity).mp.
23. (visual acuity loss or visual agnosia or visual deficit or visual deficits or visual disorder or visual disorders).mp.
24. (visual disturbance or visual disturbances or visual field defect or visual field defects or visual function).mp.
25. (visual motor or visual perception or visual problem or visual problems).mp.
26. (visual process or visual proccesses or visual processing or visual reflex).mp.
27. (visual reflexes or visual scanning or visual sequelae or visual system or visual system dysfunction or visual systems dysfunctions or visuospacial abilities or visuo-spacial abilities). mp.
28. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27
29. exp Brain Injuries/
30. exp Head Injuries, Closed/
31. exp Blast Injuries/
32. (traumatic brain injury or traumatic brain injuries or traumatic-brain-injury or tbi or mtbi or stbi or blast injury or blast injuries or blast-injury).mp.
33. 29 or 30 or 31 or 32
34. 28 and 33
35. limit 34 to yr=”2009”

Searched March 27, 2014 from January 1st, 2009 on

(Saved in OVID as “TBI EYE _2009”)

N=123(before deduplication with Medline Search)

N=89 (after deduplication with Medline Search)

### PsycINFO (OVID)

1. exp Visual Perception/
2. exp Visual Acuity/
3. exp Vision Disorders/
4. (amblyopia or binocular visionsysfunction or binocular vision dysfunctions).mp
5. (binocular visual dysfunction or binocular visual dysfunctions or blind*).mp
6. (blindness or convergence insufficiency or cranial nerve evaluation or cranial nerve evaluations).mp
7. (dark adapt* or diplopia or facial recognition or fixation defect or fixation defects).mp
8. (hemianopsia or light sensitiv* or nystagmus or ocular disease surface index).mp
9. (ocular examination or ocular examinations or ocular health or ocular migraine or ocular migraines).mp
10. (ocular pain or ocular surface stain* or ocular trauma or oculo-motor disorder).mp
11. (oculo-motor disorders or ODSI or ophtahlmolog* or optometr* or photic stimulation).mp
12. (photosensitivities or photosensitivity or pursuit abmormalit* or quadrantonopsia).mp
13. (spacial neglect or strabismus or tear film break-up time or tear osmolarity or tear production or tfbut).mp
14. (vertical heterophoria or vision accomidation or vision acuity or vision acuity loss).mp
15. (vision agnosia or vision deficit or vision deficits or vision disorder or vision disorders).mp
16. (vision disturbance or vision disturbances or vision field defect or vision field defects or vision function or vision motor).mp
17. (vision perception or vision problem or vision problems or vision process or vision proccesses).mp
18. (vision proccessing or vision reflex or vision reflexes or vision scanning or vision sequelae or vision system).mp
19. (vision system dysfunction or vision system dysfunctions or visiospacial ability or visual accomidation or visual acuity).mp
20. (visual acuity loss or visual agnosia or visual deficit or visual deficits or visual disorder or visual disorders).mp
21. (visual disturbance or visual disturbances or visual field defect or visual field defects or visual function).mp
22. (visual motor or visual perception or visual problem or visual problems).mp
23. (visual process or visual proccesses or visual processing or visual reflex).mp
24. (visual reflexes or visual scanning or visual sequelae or visual system or visual system dysfunction or visual systems dysfunctions or visuospacial abilities or visuo-spacial abilities).mp
25. (traumatic brain injury or traumatic brain injuries or traumatic-brain-injury or tbi or mtbi or stbi or blast injury or blast injuries or blast-injury).mp
26. exp “Eye (Anatomy)”/
27. exp Vision/
28. exp Traumatic Brain Injury/
29. exp Head Injuries/
30. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 26 or 27
31. 25 or 28 or 29
32. 30 and 31
33. limit 32 to yr=”2009 -Current”

Searched March 27, 2014 from January 1st, 2009 on

(Saved in OVID as “TBI EYE _2009 PsycINFO”)

N=240 (before deduplication with Medline & Cochrane Searches)

N=130 (after deduplication with Medline & Cochrane Searches)

### SPORTDiscus with Full Text, Rehabilitation & Sports Medicine Source (EBSCO)

Rehabilitation & Sports Medicine Source & SportDiscus with Full Text (searched together) (EBSCO)

S14 Limiters - Publication Date: 20090101-20141231
S13 S6 AND S12
S12 S7 OR S8 OR S9 OR S10 OR S11
S11 TI blast OR AB blast
S10 TI tbi OR AB tbi OR TI mtbi OR AB mtbi OR TI stbi OR AB stbi
S9 TI traumatic brain injury OR AB traumatic brain injury OR TI traumatic brain injuries OR AB traumatic brain injuries OR TI traumatic-brain-injury OR AB traumatic-brain-injury
S8 DE “HEAD injuries” OR DE “HEAD injuries -- Complications” OR DE “HEAD injuries -- Prevention”
S7 DE “BRAIN -- Wounds & injuries” OR DE “BRAIN -- Concussion” OR DE “BRAIN damage” OR DE “CHRONIC traumatic encephalopathy”
S6 S1 OR S2 OR S3 OR S4 OR S5
S5 TI visual OR AB visual
S4 TI vision OR AB vision
S3 (eye) OR (DE “EYE” OR DE “INTRAOCULAR pressure”)
S2 DE “VISION disorders” OR DE “BLINDNESS” OR DE “EYE -- Refractive errors” OR DE “HYPERMETROPIA”
S1 DE “VISION” OR DE “MOTION perception (Vision)” OR DE “VISUAL acuity” OR DE “VISUAL discrimination” OR DE “VISUAL evoked response” OR DE “VISUAL fields” OR DE “VISUAL perception” OR DE “VISUALIZATION”

Searched March 14, 2014 from January 1st, 2009 on

(Saved in EBSCO as “TBI EYE >2009 “)

N= 130 (before deduplication with Medline & Cochrane Searches & PsycINFO)

N= 125 (after deduplication with Medline & Cochrane Searches & PsycINFO)

### Rehabdata (National Rehabilitation Information Center http://www.naric.com/?q=en/REHABDATA)

Search Strategy: Visual Impairment (descriptor) AND Brain Injuries (descriptor) 2009 to present

Searched March 14, 2014

N=22 (after deduplication with all above searches)