# TECHNICAL EXPERT PANEL

- Glenn Cockerham, MD
  National Program Director
  VA Ophthalmology Services
  VA Palo Alto Health Care System
  Palo Alto, CA
- Gregory L. Goodrich, PhD
  Supervisory Research Psychologist and Optometric Research Fellowship Coordinator
  VA Palo Alto Health Care System
  Menlo Park, CA
- Randy Kardon, MD, PhD
  Director, Center of Excellence for Prevention and Treatment of Visual Loss
  Iowa City VAMC
  Iowa City, IA
- Terri K. Pogoda, PhD
  Research Health Scientist
  Center for Healthcare Organization and Implementation Research
  VA Boston Healthcare System
  Boston, MA