# SUMMARY AND DISCUSSION

## SUMMARY POINTS

- Only one good quality randomized trial of a newer generation continuous flow ventricular assist device as destination therapy has been reported to date. This study found that patients who received the HeartMate II had better survival, fewer major complications, spent less time in the hospital, and that their heart failure had substantially less adverse impact on their quality of life than those who received the older generation pulsatile flow HeartMate XVE device.
- Currently, selection of patients for destination therapy is based on the FDA approved indication and CMS criteria for coverage of Medicare beneficiaries that are based on enrollment criteria used by pivotal randomized controlled clinical trials. Studies have not validated use of other preoperative variables to further refine patient selection and thereby improve patient outcomes.
- Only one industry-funded cost-effectiveness analysis has been reported to date. This analysis reported costs from a third payer perspective and found that the incremental cost effective ratio was approximately $200,000 per quality-adjusted life year compared to optimal medical management.

## LIMITATIONS

At this time there is limited, but encouraging, data to support use of the FDA approved continuous flow ventricular assist device as destination therapy. Only one randomized clinical trial has been completed. Patients enrolled in the clinical trial were carefully selected thereby limiting the ability to generalize the results. Outcomes continue to improve with experience in selecting patients, surgical procedures to implant ventricular assist devices and postoperative patient care.

The reviewed literature did not identify any VA medical center that has enrolled patients in a clinical trial or the national INTERMACS registry. The number of veterans who would meet the current selection criteria for using a left ventricular assist device as destination therapy is not known. Additional data and analyses are needed to estimate the costs the Veterans Health Administration would incur to provide this highly-specialized care.

## RECOMMENDATIONS FOR FUTURE RESEARCH

Additional high-quality data are needed to inform clinical practices and policies regarding the use of ventricular assist devices to treat patients with end-stage heart failure who are not eligible for a heart transplant. Investigators suggest the following recommendations regarding future research:

- Create or participate in a registry of all Veterans that receive an LVAD as destination therapy, and support enrollment of Veterans in ongoing, randomized controlled clinical trials.
  Given the small number of patients who have received destination therapy and the rapidly evolving devices and practices, it is imperative to learn as much as possible from patients who undergo this procedure. All Veterans that receive destination therapy approved by the Veterans Health Administration should be entered into a national registry in a way that will allow separate analyses and comparisons of patient characteristics and outcomes. In addition, enrollment of patients into randomized controlled clinical trials should be encouraged. For example, a study comparing a third generation ventricular assist device to FDA-approved devices is currently trying to enroll up to 450 patients who, for the most part, meet current criteria for destination therapy.25 As ventricular assist devices become more durable with fewer complications they are also being tested in patients with less severe heart failure given concerns that the operative risk of many patients who meet the current criteria for destination therapy is too high, and patients with a less dire prognosis without a device may benefit from increasingly reliable devices.4,5 Permission to enroll patients in this study of a currently unapproved use of a newer device (HeartWare) should be considered to increase patient access to destination therapy.
- Validate and, if necessary, update prediction models especially for early postoperative mortality.
  Patients who die in the hospital soon after implantation of a ventricular assist device do not benefit. A validated prediction model for early/postoperative mortality could be applied to avoid high risk and costly attempts to use ventricular assist devices as destination therapy. Ideally clinical trials would be done to show that use of an outcome prediction model improves patient outcomes. This review did not find any established or proposed threshold for predicted risk of post operative mortality that would preclude use of destination therapy or generally be acceptable to patients and health care providers.
- Develop decision aids to help providers share information about the benefits, risks and care needed when using an approved ventriclualr assist device as destination therapy and to help them make decisions that are consistent with the informed patient’s values and preferences.
  The difficult decision to employ a ventricular assist device as destination therapy typically is made when patients are in poor health and have a very limited life expectancy without the device. A number of benefits and risks need to be explained in ways patients can understand including the uncertainty inherent in the outcomes data. Patients need to understand the follow-up care that will be required. Future states of health when the patient might want the device to be turned off need to be anticipated and discussed. Decisions aids can enhance provider-patient communication and increase patients’ knowledge and participation and acceptance of the decision.37
- Update the cost-effectiveness model as more data become available and incorporate a probabilistic sensitivity analysis.
  There have been large improvements in the cost-effectiveness of destination therapy during the past decade.35,36 It will be important to keep updating the cost-effectiveness models as the devices and related procedures improve. This is particularly important for the model parameters that appear to be most influential i.e., long-term survival both on the device and with optimal medical management, cost of the device, cost of initial hospitalization, rehospitalization rate and utility estimates based on measures of health-related quality of life. Additionally, adding probabilistic sensitivity modeling would help decision makers better understand the uncertainty of the estimates in the model by estimating confidence intervals around the incremental cost-effectiveness estimates. This can be done by using distributions of the model parameters with Monte Carlo simulation to assess the probability the incremental cost effectieness ratio will be less than or greater than various dollar amounts. Probabilistic sensitivity analyses that took the UK National Health Service payer perspective have been completed for the cost-effectiveness of continous flow LVAD as a bridge to transplant providing a good example of what could be done for destination therapy.38
- Conduct a budget impact analysis.
  Cost-effectiveness analyses provide general estimates from a societal perspective or the perspective of a generic third party payer, however, additional budget impact analyses would be useful to help the Veterans Health Administration understand the potential impact of different strategies and policies for providing destination therapy. For example, it would be important to know how many veterans would be eligible and interested in the treatment and what the options would be in terms of how and where this therapy would be provided.

## CONCLUSIONS

### Key Question #1

Use of the FDA-approved HeartMate II rather than the HeartMate XVE left ventricular assist device results in superior patient outcomes (better survival and daily existence, fewer harmful complications). [moderate strength evidence]

### Key Question #2

Preoperative correlates of patient outcomes have not been established as patient selection criteria that can lead to better patient outcomes. [insufficient evidence]

### Key Question #3

The cost-effectiveness of HeartMate II ventricular assist device for destination therapy has been estimated to be approximately $200,000 per quality-adjusted life year when compared to optimal medical management. [low strength evidence]