# RESULTS

## LITERATURE SEARCH

Figure 2 summarizes the literature search. We reviewed 1,637 titles and abstracts from the electronic search. After applying inclusion/exclusion criteria, 1,491 references were excluded. We retrieved 146 full-text articles for further review and 140 were excluded. We identified 1 additional reference by hand-searching references lists and 2 articles that were published after our search date. There were a total of 4 articles (3 from the literature search) for Key Question #1; only one was a randomized controlled trial. There were 4 articles included for Key Question #2 (3 from the literature search); 3 examined prediction models and 1 was a subgroup analysis. For Key Question #3, 1 article was included that was published after the initial literature search.

Figure 2 Literature Flow Diagram

## KEY QUESTION #1 How does use of an FDA-approved, current generation LVAD as destination therapy (i.e., the HeartMate II left ventricular assist device) effect patient outcomes?

We found one good quality randomized clinical trial of the HeartMate II left ventricular assist device employed as destination therapy.1 Patients enrolled in this study generally met the current criteria for destination therapy that were based on a previous study of an older generation device2 including being ineligible for a heart transplant, most being in NYHA association class IV heart failure that was refractory to optimized therapies, a left ventricular ejection fraction less than 25% and very limited ability to exercise. The subjects’ (n=200) mean age was 62 years and 84% were males. Compared to the older generation HeartMate XVE left ventricular assist device, use of the HeartMate II provided superior patient outcomes (See Appendix D, Table 1). After 24 months, the primary endpoint of survival free of disabling stroke or reoperation to remove the device was 46% versus 11%, respectively (p < 0.0001). Survival in the HeartMate II group was significantly better (58% versus 24% after 2 years) and subjects spent a greater percentage of their follow-up time outside of a hospital (88% versus 74%) largely due to a lower readmission rate. During follow-up, survivors with the HeartMate II also had fewer limitations due to heart failure as measured by the NYHA class, Minnesota Living with Heart Failure Questionnaire and clinical component of the Kansas City Cardiomyopathy Questionnaire. The incidences of several adverse events were lower as well including right heart failure, cardiac arrhythmias, device-related infections, sepsis, respiratory failure, renal failure and device replacement. None of the adverse events rates were higher in the HeartMate II group including major bleeding and strokes. This study provides moderate quality evidence that numerous patient outcomes in patients treated with the HeartMate II are better than the HeartMate XVE when used for destination therapy. Since patient characteristics and outcomes in the HeartMate XVE arm of this study were similar to those in the previous clinical trial that demonstrated the HeartMate XVE provided superior outcomes compared to optimal medical therapy,2 one might infer that the HeartMate II would also be superior to optimal medical therapy.

A recent fair quality report23 compared outcomes of patients enrolled in a continued access protocol to those who received the HeartMate II in the above randomized clinical trial (Appendix D, Table 1). Patient selection criteria and baseline characteristics in the continued access protocol were essentially the same as the randomized controlled trial. The patients enrolled in the continued access protocol had as good or better outcomes. After 24 months, the primary endpoint of survival free of disabling stroke or reoperation to remove the device was 50% in the group assigned to the HeartMate II in the randomized controlled trial versus 59% in the continued access protocol (p=0.07). Survival for 2 years was also similar 58% versus 63%, respectively. During follow-up survivors also had similar improvements in symptoms and related quality of life as measured by the NYHA class, Minnesota Living with Heart Failure Questionnaire and the Kansas City Cardiomyopathy Questionnaire. The incidences of hemorrhagic stroke, bleeding treated with packed red blood cells, sepsis and device-related infection were significantly lower in the group enrolled in the continued access protocol. The reduction in bleeding events was attributed to changes in the postoperative use of less aggressive anticoagulation regimens. There were no differences in the incidences of other adverse effects.

Two reports of case series3,24 provided survival estimates for patients receiving the Heart Mate II as destination therapy (Appendix D, Table 1). Although these reports provided lower quality evidence, survival at one year in these cases series was similar to the 68% 1-year survival in the HeartMate II group in the randomized clinical trial. More recent survival estimates without heart transplantation or heart recovery from the INTERMACS registry that are based on 740 cases were 74% and approximately 60% after 1 and 2 years, respectively.13 The available survival estimates are remarkably consistent with each other.

### Summary of Findings for Key Question #1

A single good quality study provided evidence that use of the newer, continuous flow HeartMate II ventricular assist device for destination therapy provides better patient outcomes than the older, pulsatile flow HeartMate XVE device. A fair quality continued access protocol for use of the HeartMate II indicated that all of the reported patient outcomes continue to be as good as those seen in the randomized controlled trial or better including significantly fewer hemorrhagic strokes, major bleeding episodes and infections. Case series have also reported similar survival when the HeartMate II was used as destination therapy.

Clinical trials of other continuous flow devices for destination therapy such as a HeartWare device with a different continuous flow design are ongoing,4,5,25 however results are not expected for several years.

## KEY QUESTION #2 What patient or site characteristics have been associated with patient benefits or harms when the FDA-approved, current generation LVAD is used as destination therapy?

Based on the approved FDA indication and clinical trials, CMS has determined that the evidence is adequate to conclude that implantation of a left ventricular assist device approved by the FDA for destination therapy is reasonable and necessary for Medicare beneficiaries who have chronic end-stage heart failure, are not candidates for heart transplantation, and meet all of the following conditions: 1) NYHA Class IV symptoms of heart failure that have not responded to optimal medical management including dietary salt restriction, diuretics, digitalis, beta-blockers and angiotensin converting enzyme inhibitors (if not tolerated, presumably angiotensin receptor blockers would be an acceptable alternative) for at least 45 of the last 60 days or have been balloon pump dependent for 7 days, or IV inotrope dependent for 14 days (cardiac resynchronization therapy and an implantable cardiac defibrillator are not listed although they have become standards of care when clinically indicated for patients with heart failure), 2) a left ventricular ejection fraction less than 25%, 3) demonstrated functional limitation with a peak oxygen consumption of 14 ml/kg/min or less unless the patients is balloon pump or inotrope dependent or physically unable to perform an exercise test and 4) appropriate body size for the device.12

In addition, CMS determined that destination therapy is reasonable and necessary only when the procedure is performed in a facility approved under the Disease-Specific Care Certification Program for Ventricular Assist Device developed by the Joint Commission on Accreditation of Healthcare Organizations.26 Facility staff must have implanted at least 10 ventricular assist devices or total artificial hearts as a bridge to transplant or as destination therapy during the past 36 months with at least one procedure within the past 18 months. The facility also must have in place staff and processes that assure that prospective recipients receive all information necessary to assist them in giving informed consent for the procedure, and so that they and their families are fully aware of the aftercare requirements and potential limitations as well as benefits. We found only one study of patient preferences related to use of ventricular assist devices that explored a few hypothetical situations describing life expectancy and daily function without the device.27

The CMS criteria also state that the facility must be an active, continuous member of a national, audited registry that requires submission of data on all destination therapy patients from the date of implantation throughout the remainder of the recipient’s lives. The INTERMACS registry satisfies this CMS reporting requirement.

More detailed patient inclusion and exclusion criteria have been used in clinical trials of ventricular assist devices as destination therapy and are recommended by clinical experts.28,29,30,31,32

Since outcomes among patients meeting current selection criteria do vary, selection of patients could be refined using strong predictors of patient outcomes. Clearly, there is little or no benefit to patients that don’t recover from the operation to implant a ventricular assist device. A validated method to determine which eligible patients have unacceptably high (not defined) operative risk might improve patient selection and outcomes. A report of INTERMACS data summarized in Appendix D, Table 2 indicated that the presence of cardiogenic shock, concomitant surgery and poorer renal function as indicated by higher blood urea nitrogen were associated with higher mortality within 30 days of the operation.3 This analysis focused on use of ventricular devices as destination therapy but included many cases that received the obsolete HeartMate XVE. Interactions between the type of device and operative risk factors were not reported to determine whether the prognostic information depended on the type of device. More importantly, the risk factors were not used to identify patients that have an unacceptably high operative risk, and the confidence one would have in selecting patients based on the predicted probabilities of operative mortality risk was not reported.

Lietz et al. analyzed data in the manufacturer’s registry of HeartMate XVE use post-FDA approval to develop a risk model of 90-day in hospital mortality.11 The risk model incorporated several preoperative variables as summarized in Appendix D, Table 2. The risk score derived from this model discriminated the two outcome groups and could place patients into risk groups that had substantially different levels of risk. However, the difference in predicted and observed outcomes was substantial in some risk groups and the precision of the estimates was inadequate in the smaller risk groups. Furthermore, there was no consensus about which, if any, risk groups should be excluded from treatment due to high risk. We found no reports that tried to validate or update this risk model for current practices that use the HeartMate II device.

Current criteria for use of a ventricular assist device as destination therapy include an estimated 1-year survival without the device of less than 50%^14^ or an overall life expectancy of less than 2 years.10,12 A validated method for making these predictions has not been established. As summarized in Appendix D, Table 2, Levy et al. adapted and evaluated the Seattle Heart Failure Model to predict survival of the patients in the optimal medical therapy arm of the initial clinical trial of the HeartMate VE.33 There was good agreement between the observed and predicted 1-year survival (28% versus 30%), and 81% met the guideline criterion of less than 50% predicted probability of survival for one year without a ventricular assist device. No further studies were found that indicated use of this prediction model would improve selection of patients for destination therapy or patient outcomes.

A secondary analysis of clinical trial data collected at a single center suggested that carefully selected patients that were 70 years old or older (a commonly used cutoff for heart transplantation) had similar outcomes to those less than 70 years old.34 However as summarized in Appendix D, Table 2, there were only a small number of patients in this comparison and there were no adjustments for preoperative differences.

### Summary of Findings for Key Question #2

The scientific evidence concerning use of newer generation, continuous flow FDA-approved ventricular assist devices, i.e., the HeartMate II, is insufficient to refine patient selection criteria for destination therapy beyond the current criteria used to enroll patients in the pivotal clinical trials and determine eligibility for CMS coverage.

A few studies have identified risk factors for mortality and developed or applied prediction models to this particular patient population. Further studies are needed to validate the use of different criteria to select patients and improve patient outcomes. An ongoing clinical trial is selecting less severely ill patients and may expand the criteria for use of a newer generation continuous flow devices as destination therapy.4,5 In the meantime, the approved FDA indication and CMS criteria for coverage are available.

## KEY QUESTION #3 What is the range of cost-effectiveness estimates of using the FDA-approved, current generation LVAD as destination therapy in end-stage heart failure and what explains variation in these estimates?

As reported in the results for Key Question #1, we identified one randomized trial comparing a current generation continuous flow ventricular assist device (HeartMate II) to the older generation (HeartMate XVE) ventricular assist device.1 There was also one prior trial comparing an older generation HeartMate VE device to optimal medical management.2 There have been no studies that directly compared a current generation device to optimal medical management. We found only one analysis of cost-effectiveness that used data from these two prior trials to indirectly estimate the cost-effectiveness of using the HeartMate II ventricular assist device for destination therapy compared to optimal medical management.35

Rogers et al. estimated that the continuous-flow device would have an incremental cost effectiveness ratio (ICER) of $198,184 per quality-adjusted life year and $167,208 per overall life years not adjusted for in the patients’ quality of life.35 Estimates of confidence intervals around these cost-effectiveness ratios were not reported. The analysis was funded by the maker of the device and the costs were assessed from the perspective of a third-party payer, not necessarily the VA. Details of this analysis related to the key model components, source data, and the effect sensitivity analyses are summarized in Appendix D, Table 3. The ICER estimates used “base case” assumptions regarding: survival that included the 24-month estimates from the clinical trials with extrapolation of survival thereafter, costs related to the initial implantation of the ventricular assist device, costs of medical management, re-hospitalization rates and costs, device replacement costs, outpatient care costs, end-of-life costs and estimates of quality of life (utility) for each of the four NYHA classes of limitations due to symptoms of heart failure that patients may fall in after implantation of the device. The quality of life assessment did not incorporate other medical conditions including the impact of device complications. Limited sensitivity analyses that changed one model component at a time suggested that the variation in the cost-effectiveness estimates were most dependent on the extrapolated estimates of survival from 24 to 60 months and the costs of the initial implantation of the ventricular assist device and subsequent re-hospitalizations for complications. Plausible changes to any of these individual assumptions resulted in estimates of cost-effectiveness ranging from $150,000 to $300,000 per quality-adjusted life year.

Prior analyses that compared use of the older generation ventricular assist device (HeartMate VE) to optimized medical management reported a cost-effectiveness ratio of $802,700 per quality-adjusted life year.36 Rogers’ adaptation of this model for the HeartMate II appeared to show a significant improvement in the cost-effectiveness. The main drivers of the improvement in cost-effectiveness were not well established, however, Rogers et al. state that the improvement was largely due to better survival, reductions in implant costs and better quality of life of surviving patients that received the device.35 Nevertheless, destination therapy remains among the least cost-effective interventions covered by Medicare.6

### Summary of Findings for Key Question #3

The estimated cost-effectiveness of using the HeartMate II as destination therapy for patients with end-stage heart failure was approximately $200,000 per quality-adjusted life year. The cost-effectiveness estimates did not drop below $150,000 even with more favorable assumptions regarding the outcomes or costs of using the HeartMate II ventricular assist device as destination therapy.