# REFERENCES

1 Slaughter MS, Rogers JG, Milano CA, et al. for the HeartMate II Investigators. Advanced heart failure treated with continuous-flow left ventricular assist devices. N Engl J Med. 2009;361:2241-51. [pmid: 19920051].
2 Rose EA, Gellins AC, Moskowitz AJ, et al. for the REMATCH Study Group. Long-term use of a left ventricular assist device for end-stage heart failure. N Engl J Med. 2001;345:1435-43. [pmid: 11794191].
3 Kirklin JK, Naftel DC, Kormos RL, et al. Third INTERMACS annual report: The evolution of destination therapy in the United States. J Heart Lung Transplant. 2011;30:115-23. [pmid: 21215378].
4 Baldwin JT, Mann DL. NHLBI’s program for VAD therapy for moderately advanced heart failure: The REVIVE-IT pilot trial. J Card Fail. 2010;16:855-8. [pmid: 21055648].
5 ClinicalTrials.gov. The evaluation of VAD InterVEntion before inotropic therapy (REVIVE-IT). NCT01369407. Available at http://clinicaltrials.gov/ct2/show/record/NCT01369407. Accessed December 19, 2011.
6 Chambers JD, Neumann PJ, Buxton MJ. Does Medicare have an implicit cost-effectiveness threshold?. Med Decis Making. 2010;30(4):E14-E27. [pmid: 20551473].
7 Miller LW. Is left ventricular assist device therapy underutilized in the treatment of heart failure?. Circulation. 2011;123:1552-8. [pmid: 21482973].
8 Terracciano CM, Miller LW, Yacoub MH. Contemporary use of ventricular assist devices. Annu Rev Med. 2010;61:255-70. [pmid: 20059338].
9 John R, Naka Y, Smedira NG, et al. Continuous flow left ventricular assist device outcomes in commercial use compared with the prior clinical trial. Ann Thorac Surg. 2011;92:1406-13. [pmid: 21958789].
10 FDA Device Approvals and Clearances. HeartMate® SNAP-VE LVAS - P920014/S016. Available at http://www.accessdata.fda.gov/cdrh_docs/pdf/p920014s016a.pdf. Accessed April 27, 2012.
11 Lietz K, Long JW, Kfoury AG, et al. Outcomes of left ventricular assist device implantation as destination therapy in the post-REMATCH era. Circulation. 2007;116:497-505. [pmid: 17638928].
12 Centers for Medicare & Medicaid Services. Decision Memo for Ventricular Assist Devices as Destination Therapy (CAG-00119N) issued in October 2003 with revisions in March 2007 (CAG-00119R1) and November 2010 (CAG-00119R2). Available at https://wwwcmsgov/medicare-coverage-database/details/nca-decision-memo.aspx?NCAId=79&ver=6&NcaName=Ventricular+Assist+Devices+as+Destination+Therapy&bc=BEAAAAAAEAAA&&fromdb=true. Accessed December 2, 2011.
13 Kirklin JK, Naftel DC, Kormos RL, et al. Fourth INTERMACS annual report: 4,000 implants and counting. J Heart Lung Transplant. 2012;31:117-26. [pmid: 22305376].
14 Jessup M, Abraham WT, Casey DE, et al. writing on behalf of the 2005 Guideline Update for the Diagnosis and Management of Chronic Heart Failure in the Adult Writing Committee. 2009 Focused update: ACCF/AHA guidelines for the diagnosis and management of heart failure in adults. Circulation. 2009;119:1977-2016. [pmid: 19324967].
15 Lindenfeld J, Albert NM, Boehmer JP, et al. HFSA 2010 Comprehensive Heart Failure Practice Guideline. Available at http://www.heartfailureguideline.org. Accessed December 2, 2011.
16 McKelvie RS, Moe GW, Cheung A, et al. The 2011 Canadian Cardiovascular Society heart failure management guidelines updates: Focus on sleep apnea, renal dysfunction, mechanical circulatory support, and palliative care. Can J Cardiol. 2011;27:319-38. [pmid: 21601772].
17 Parides MK, Moskowitz AJ, Ascheim DD, Rose EA, Gelijns AC. Progress versus precision: Challenges in clinical trial design for left ventricular assist devices. Ann Thorac Surg. 2006;82:1140-6. [pmid: 16928569].
18 Patel-Raman SM, Chen EA. Past, present, and future regulatory aspects of ventricular assist devices. J Cardiovasc Transl Res. 2010;3:600-3. [pmid: 21046301].
19 Neaton JD, Normand S-L, Gelijns A, Starling RC, Mann DL, Konstam MA. Designs for mechanical circulatory support device studies. J Cardiac Fail. 2007;13:63-74.
20 Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. (updated March 2011). The Cochrane Collaboration. 2011. Available at http://www.cochrane-handbook.org/. Accessed August 29, 2011.
21 Sculpher M, Fenwick E, Claxton K. Assessing quality in decision analytic cost-effectiveness models. A suggested framework and example of application. Pharmacoeconomics. 2000;17:461-77. [pmid: 10977388].
22 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. 2010;63(5):513-523. [pmid: 19595577].
23 Park SJ, Milano CA, Tatooles AJ, et al. for the HeartMate II Clinical Investigators. Outcomes in advanced heart failure patients with left ventricular assist devices for destination therapy. Circ Heart Fail. 2012. Jan. 26. Epub ahead of print.
24 Strüber M, Kander K, Lahpor J, et al. HeartMate II left ventricular assist device; early European experience. Eur J Cardiothorac Surg. 2008;34:289-94. [pmid: 18571932].
25 ClinicalTrials.gov. A clinical trial to evaluate the HeartWare® ventricular assist system (ENDURANCE). NCT01166347. Available at http://clinicaltrials.gov/ct2/show/record/NCT01166347. Accessed December 8, 2011.
26 Joint Commission, The. Advanced Certification in Ventricular Assist Device. Available at http://www.jointcommission.org/certification/ventricular_assist_device.aspx. Accessed March 2, 2012.
27 Stewart CG, Brooks K, Pratibhu PP, et al. Thresholds of physical activity and life expectancy for patients considering destination ventricular assist devices. J Heart Lung Transplant. 2009;28:863-9. [pmid: 19716036].
28 Lietz K, Miller LW. Patient selection for left-ventricular assist devices. Curr Opin Cardiol. 2009;24:246-51. [pmid: 19318935].
29 Lietz K. Destination therapy: patient selection and current outcomes. J Card Surg. 2010;25:462-71. [pmid: 20529162].
30 Slaughter MS, Pagani FD, Rogers JG, et al. for the HeartMate II Clinical Investigators. Clinical management of continuous-flow left ventricular assist devices in advanced heart failure. J Heart Lung Transplant. 2010;29:S1-S39. [pmid: 20181499].
31 Tang DG, Oyer PE, Mallidi HR. Ventricular assist devices: History, patient selection, and timing of therapy. J Cardiovasc Transl Res. 2009;2:159-67. [pmid: 20559983].
32 Wilson SR, Mudge GH, Stewart GC, Givertz MM. Evaluation for a ventricular assist device. Circulation. 2009;119:2225-32. [pmid: 19398678].
33 Levy WC, Mozaffarian D, Linker DT, Farrar DJ, Miller LW. on behalf of the REMATCH Investigators. Can the Seattle Heart Failure Model be used to risk-stratify heart failure patients for potential left ventricular assist device therapy?. J Heart Lung Transplant. 2009;28:231-6. [pmid: 19285613].
34 Adamson RM, Stahovich M, Chillcott S, et al. Clinical strategies and outcomes in advanced heart failure patients older than 70 years of age receiving the HeartMate II left ventricular assist device. J Am Coll Cardiol. 2011;57:2487-95. [pmid: 21679851].
35 Rogers JG, Bostic RR, Tong KB, Adamson R, Russo M, Slaughter MS. Cost-effectiveness analysis of continuous-flow left ventricular assist devices as destination therapy. Circulation:Heart Fail. 2012;5:10-6.
36 Samson D. Special report: cost-effectiveness of left-ventricular assist devices as destination therapy for end-stage heart failure. Technology Evaluation Center Assessment Program Report. 2004;19:1-36.
37 Allen LA, Stevenson LW, Grady KL, et al. Decision making in advanced heart failure, a scientific statement from the American Heart Association. Circulation. 2012;125. 00-00 online ahead of print. [doi: 10.1161/CIR.0b013e31824f2173].
38 Moreno SG, Novielli N, Cooper NJ. Cost-effectiveness of the implantable HeartMate II left ventricular assist device for patients awaiting heart transplantation. J Heart Lung Transplant. 2012;31(5):450-8. [pmid: 22115674].