# INTRODUCTION

Several common chronic conditions such as atherosclerotic heart disease and hypertension as well as other diseases can result in heart failure, a reduced ability of the heart to pump blood and maintain normal bodily functions. The prevalence of chronic heart failure increases with age to over 10% in the elderly population.7 More than 100,000 people in the United States with progressive heart failure are refractory to available treatments and have high rates of hospitalization and mortality and a poor quality of life due to limited physical and social activities and psychological stress. Heart transplantation is currently the preferred treatment for end-stage heart failure. Unfortunately, the supply of donor hearts is far less than needed and many patients do not meet the criteria for heart transplantation primarily due to old age and comorbidities such as diabetes with damage to vital organs, pulmonary hypertension, renal insufficiency, malignancies and morbid obesity.

Implantable mechanical pumps that assist the circulation of blood by one or both ventricles of the heart have evolved over several decades. Typically blood flows from the native left ventricle of the heart into the surgically implanted assist device and is pumped out into the aorta via an implanted conduit. The design of the mechanical pump varies (pulsatile fill and pump designs similar to a normal heart and continuous flow rotary pumps). Currently, long-term implantable left ventricular assist devices require an external source of power and control module.

Surgical placement of a left ventricular assist device is increasingly done as a last resort for patients with refractory heart failure who are not eligible for heart transplantation, so called destination therapy.8 Some patients may improve after they receive a ventricular assist device as destination therapy and become eligible for heart transplantation even though this was not the initial therapeutic goal. A limited number may recover enough heart function to not need a heart transplant or mechanical assist device. Although survival with a newer generation continuous flow ventricular assist device is approaching that of a heart transplant, long-term use of the device by patients who are eligible for a heart transplant is not currently accepted practice.9 Conversely, many patients that receive a ventricular assist device as a bridge to transplant use the device for increasingly prolonged periods while waiting for a donated heart and some may become ineligible for a heart transplant.

The purpose of this report is to review the scientific evidence for use of ventricular assist devices as destination therapy for patients with severe, refractory heart failure who are not eligible for heart transplantation at the time the device is implanted. Although many patients receive the same types of ventricular assist devices as a bridge to heart transplantation or recovery, the characteristics, hence risk profiles, of patients receiving bridge therapy are different from patients selected to receive a device as permanent destination therapy. Furthermore many bridged patients do receive a heart transplant that alters patient outcomes. Thus, this review focused on evidence about patient outcomes, patient selection and cost effectiveness of ventricular assist devices specifically intended as destination therapy. The primary goals of destination therapy are to:

- prolong survival,
- improve daily function and health-related quality of life,
- minimize harms including infection, major bleeding episodes, thromboembolic events including strokes and device malfunction or failure especially those that require hospital care.

## VENTRICULAR ASSIST DEVICES APPROVED FOR USE AS DESTINATION THERAPY

The first randomized controlled clinical trial of a ventricular assist device as destination therapy compared an early generation device (a ventilated electric pulsatile pump, HeartMate VE) to optimal medical therapy.2 This device significantly improved survival to 52% versus 25% at 1 year and 23% versus 8% after 2 years. Unfortunately, 35% of the surgically implanted devices failed within 2 years, and 17% of the deaths were attributed to failure of the device. The overall effect of the device, including serious complications on the subjects’ functional status and health-related quality of life, was difficult to assess due to the high, differential mortality rates and lack of assessments during early follow-up. Comparisons of the subjects that survived for one year indicated physical and emotional status were better in the group treated with the ventricular assist device. This pivotal trial led to approval by the U.S. Food and Drug Administration (FDA) in November 2002 of the left ventricular assist device (modified and now known as the HeartMate XVE) for use as destination therapy.10 The approved indication included patients that were not eligible for heart transplantation who have New York Heart Association (NYHA) class IV heart failure (shortness of breath and/or fatigue during minimal physical activity or at rest) for at least 60 of the last 90 days despite optimal medical therapy, an unassisted left ventricular ejection fraction less than 25%, and a peak oxygen consumption less than 12 ml/kg/min during an exercise stress test or continued need for an intravenous inotrope. Furthermore, the estimated life expectancy without the ventricular assist device should be less than 2 years, similar to patients that participated in the clinical trial. After FDA approval, clinical use of the HeartMate XVE was associated with a similar 56% 1-year survival, but unfavorable rates of surgical complications including sepsis, multi-organ failure, right heart failure, prolonged hospitalization and a 90-day in-hospital mortality of 27%.11 Within 2 years, 73% needed device replacement or experienced a fatal device failure.

In January 2010, a newer generation, rotary continuous flow ventricular assist device (HeartMate II) was approved by the FDA for destination therapy based on a clinical trial that compared the new ventricular assist device, the HeartMate II, to the HeartMate XVE.

## CENTERS FOR MEDICARE AND MEDICAID SERVICES (CMS) COVERAGE

In October 2003, the Centers for Medicare and Medicaid Services (CMS) decided to cover use of FDA-approved ventricular assist devices as destination therapy when provided by a Medicare-approved heart transplantation center.12 The clinical center needed to have the staff and processes to fully inform prospective recipients about the potential benefits, risks and required follow-up care. Furthermore, the center was required to report case information to a national audited registry from the date of device implantation until death. In March 2007, the facility criteria were modified to require a board-certified cardiovascular surgeon that has implanted at least 10 ventricular assist devices during the past 3 years (at least one in past 18 months) and facility certification by the Disease-Specific Care Certification Program for Ventricular Assist Device developed by the Joint Commission on Accreditation of Healthcare Organizations.

After FDA approval of the HeartMate II device for destination therapy, CMS eligibility requirements were changed to include patients that are refractory to optimal medical management for at least 45 of the past 60 days or dependent on an intra-aortic balloon pump for 7 days or an intravenous inotrope for 14 days. The peak oxygen requirement was increased to 14 ml/kg/min or less unless the patient was physically unable to do an exercise test or was dependent on a balloon pump or intravenous inotrope.

## REGISTRY OF VENTRICULAR ASSIST DEVICES USED AS DESTINATION THERAPY

An Interagency Registry for Mechanically Assisted Circulatory Support (INTERMACS) was created with support from the National Heart, Lung and Blood Institute, FDA, CMS, the device industry and health care providers. In June 2006, this registry began to collect information about patients, devices and outcomes including adverse events. The registry is focused on use of FDA-approved ventricular assist devices including destination therapy. The registry meets the CMS mandate that all hospitals in the United States that provide mechanical circulatory support as destination therapy enter their cases into a national audited registry.3 During the 6-month period from January to June 2010 (shortly after FDA approval of the new continuous flow device, HeartMate II), there was nearly a 10-fold increase in the number of registered uses for destination therapy. All registered cases during this period received the newer FDA-approved HeartMate II ventricular assist device. As of June 30, 2011, 126 medical centers had registered patients of which 101 centers were approved by CMS to provide destination therapy.13 A total of 847 patients treated with destination therapy had been registered and all recent cases employed the FDA approved continuous flow ventricular assist device, presumably HeartMate II. No VA Medical Centers were listed by the registry as of March 5, 2012 (see www.intermacs.org/membership). Patients receiving a continuous device as destination therapy had significantly worse survival than those receiving a continuous device as a bridge to transplant.

## GUIDELINE RECOMENDATIONS

A 2009 update of the 2005 American College of Cardiology Foundation/American Heart Association Task Force on Practice Guidelines for the Diagnosis and Management of Heart Failure in Adults did not modify their previous recommendation concerning destination therapy for patients with refractory end-stage heart failure (stage D).14 Consideration of a permanent left ventricular assist device continued to be considered reasonable for highly selected (undefined) patients that have estimated 1-year mortality with optimal medical therapy over 50%. This recommendation was developed in collaboration with International Society for Heart Lung Transplantation.

Guidelines issued by the Heart Failure Society of America in 2010 recommend that permanent mechanical assistance may be considered in highly selected patients with severe heart failure refractory to conventional therapy who are not candidates for heart transplantation, particularly those who cannot be weaned from inotropic support by an experienced heart failure center.15

The 2011 Canadian Cardiovascular Society Heart Failure Guidelines recommend that permanent mechanical circulatory support be considered for highly selected patients who are ineligible for heart transplantation.16 This was considered to be a ‘weak’ recommendation because of the uncertainty about the balance of benefits and risk given currently available evidence. Eligible candidates would have severe symptoms of advanced heart failure despite optimal treatment and meet at least two of the following criteria: 1) a left ventricle ejection fraction less than 25% and, if exercise stress test is done, a peak oxygen consumption less than 14 ml/kg/min, 2) progressive organ dysfunction due to hypoperfusion, 3) need to reduce standard therapies for heart failure due to symptomatic hypotension or worsening renal function, 4) more than 3 hospital admissions for refractory heart failure during the previous year or 5) unable to wean from inotropic support. Informed patient preferences were a very important component of the recommendation as was a medical center that has a multidisciplinary team with expertise in surgical implantation and follow-up of patients with ventricular assist devices.