# EVIDENCE TABLES

Table 1 Key Question #1: Effects on Patient Outcomes

Table 2 Key Question #2: Patient Selection

Table 3 Key Question #3: Cost-effectiveness